# 10 STUDY PARTICIPANTS

## 10.1 Disposition of Participants – Pediatrix Medical Group Database

The disposition of participants for the Pediatrix Medical Group Database analysis is presented in Appendix 16.4.1.

## 10.2 Disposition of Participants – Medical Chart Review

Data from infants who received acyclovir starting in 2002 or later were collected in reverse chronological order, starting with the most recent data available until the desired sample size was reached at each site. Two of the four study sites conducted the study under protocol version 4.0 which permitted data collection on eligible infants born through 12/31/2014. The other two study sites conducted the study under protocol version 2.0, with data collection on infants born through 12/31/2012.

Participant accounting is summarized by site and gestational age (GA) and postnatal age (PNA) at the first recorded dose of IV acyclovir. There were 49 participants recorded in the electronic data system with confirmed (48 participants) or suspected (1 participant ▬▬▬▬▬) HSV who received IV acyclovir per standard of care at▬▬▬▬▬ (▬, n=20), ▬▬▬▬▬ (▬ n=9), ▬▬▬▬▬ (▬, n=7) and ▬▬▬▬▬ (▬, n=13).

The safety population was comprised of participants who received IV acyclovir per standard of care and included all 49 participants. Per the inclusion criteria defined in the protocol, participants should have at least 21 days of IV acyclovir therapy unless the participants died prior to day 21 of therapy. Seven participants received <21 days of IV acyclovir therapy at the study site and did not die during hospitalization for acyclovir therapy. Five participants ▬▬▬▬▬ were discharged home to complete the 21 days of therapy, one participant (▬▬▬▬▬) started the acyclovir course prior to admission to the study site, and one participant (▬▬▬▬▬) was discharged home for palliative care. All 7 participants are included in the safety population. Data regarding acyclovir dosing and safety events outside of the study site are not available for inclusion in this analysis.

### 10.2.1 Protocol Deviations and Waivers

Not applicable.

### 10.2.2 Data Sets Analyzed

All 49 participants are included in the safety analyses.

### 10.2.3 Demographic and Other Baseline Characteristics

Baseline demographics and other characteristics are summarized by GA and PNA group and site in Table 14.1.1 and 14.1.2.

There were 6 participants in the GA 23-29 weeks group; 10 in the GA 30-34 weeks group; 25 participants enrolled in the GA 35-42 weeks and PNA <14 days group; and 8 participants in the GA 35-42 weeks and PNA ≥14 days group. Median gestational age of the participants was 38 weeks (range 24 to 41) and the median postnatal age was 8 days (range 0 to 90). Twenty-five participants (51%) were male. Three participants (6%) were reported to be of Hispanic or Latino ethnicity, all 3 Hispanic or Latino participants were in GA 35-42 weeks and PNA <14 days group. Twenty-one participants (43%) were of white or Caucasian race, 15 (31%) were black or African American, 1 (2%) reported other races and 12 (24%) did not report their race. Median birth weight was 2990 g (range 590 to 4054). Participants had a median 30 days (range 2 to 182) in hospital following birth. Nine participants (18%) were inborn. Twenty-one (43%) participants had caesarean section for delivery. All 49 participants had confirmed herpes simplex virus (HSV).

### 10.2.4 Drug Dose

Doses administered are grouped by GA and PNA group and site in Table 14.3.1.1, Table 14.3.1.2, Table 10-1. The summary is based on the mean and max dose for each participant during the study period. Only IV acyclovir doses are included in the summary.

The median mean daily study dose per kg of participant dosing weight was 58.8 mg/kg (20.1 - 431.4). Participants in the GA 23-29 weeks group received highest mean daily study dose with median of 74.7 mg/kg (20.1 – 134.1); the other 3 GA and PNA group had similar mean daily study doses per dosing weight. The max median daily study dose per kg of participant dosing weight was 77.3 mg/kg (20.1 – 441.2). Participants in GA 23-29 weeks group received highest max daily study dose with median of 160.3 mg/kg (20.1 – 220.9); the other 3 GA and PNA group had similar max daily study doses per dosing weight. The median cumulative study dose per kg of participant dosing weight was 1292 mg/kg (20 – 7178). Participants in the GA 23-29 weeks group received the highest cumulative study dose with a median of 2211 mg/kg(20 – 7178); the other 3 GA and PNA group had similar cumulative study dose per dosing weight per day. Participants at the ▬ site received the highest mean, max and cumulative study dose with a median of 90.0 mg/kg/day (28.3 – 431.4), 103.8 mg/kg/day (60.0 – 441.2) and 1880 mg/kg (558 – 7178), respectively. Participants at the ▬ site had lowest median cumulative study dose 540 mg/kg (60 – 2540).

The median duration of study treatment is 22 days (1 - 82) and the youngest GA 23-29 weeks group had the shortest median study treatment 10 days (2 - 43).

Table 10-1 Doses Administered by GA and PNA group

| GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
Mean Study Dose (mg/kg/day)
N | 6 | 10 | 25 | 8 | 49
Mean (SD) | 75.1 (45.0) | 76.9 (37.2) | 78.0 (77.8) | 61.4 (9.1) | 74.7 (59.5)
Median (Min, Max) | 74.7 (20.1 - 134.1) | 58.9 (46.7 - 161.8) | 58.8 (28.3 - 431.4) | 57.7 (51.9 - 79.6) | 58.8 (20.1 - 431.4)
Max Study Dose (mg/kg/day)
N | 6 | 10 | 25 | 8 | 49
Mean (SD) | 133.7 (77.6) | 102.3 (79.5) | 92.8 (79.3) | 75.0 (16.5) | 96.8 (72.5)
Median (Min, Max) | 160.3 (20.1 - 220.9) | 72.2 (59.4 - 318.2) | 61.2 (39.5 - 441.2) | 71.0 (58.7 - 95.8) | 77.3 (20.1 - 441.2)
Cumulative Study Dose (mg/kg)
N | 6 | 10 | 25 | 8 | 49
Mean (SD) | 2477 (2614) | 1554 (959) | 1621 (1603) | 1124 (248) | 1631 (1521)
Median (Min, Max) | 2211 (20 - 7178) | 1332 (140 - 3398) | 1319 (60 - 6471) | 1251 (558 - 1276) | 1292 (20 - 7178)
Duration of Study Treatment (days)
N | 6 | 10 | 25 | 8 | 49
Mean (SD) | 25 (22) | 20 (11) | 20 (16) | 19 (6) | 21 (14)
Median (Min, Max) | 25 (1 - 62) | 21 (3 - 43) | 21 (2 - 82) | 22 (7 - 22) | 22 (1 - 82)