# 9 INVESTIGATIONAL PLAN

## 9.1 Overall Design and Plan Description

### 9.1.1 Pediatrix Medical Group (Administrative Database Review)

All infants with confirmed or suspected HSV in the PMG administrative database, discharged between 2002 and 2012, who received acyclovir per standard of care, were identified to evaluate the safety of acyclovir treatment. This was anticipated to include approximately 800 infants. Data collected was limited to 2002 and afterwards as HD study results did not become available until 2002 [4].

Data on subject demographics, clinical characteristics, AEs, laboratory and microbiology results were extracted as shown in Table 9-1. Information on acyclovir administration included days of administration; however, the administrative database did not include dosing.

Table 9-1 Variables Collected From the Pediatrix Database

| Day of birth | Days −1 to −3 | On acyclovir | Days +1 to +3 | Discharge
Demographics
Gender | X
Admission day of life | X
Discharge year | | | | | X
Discharge day of life | | | | | X
Gestational age | X
Postnatal age | | | X
Birth weight | X
Race/ethnicity | X
Inborn/outborn | X
Mode of delivery | X
Adverse Events
Hypotension requiring pressors | | | X
Medical Necrotizing Enterocolitis (NEC) | | | X
Surgical NEC | | | X
Spontaneous intestinal perforation | | | X
Grade II Intraventricular Hemorrhage (IVH) | | | X
Grade III or IV IVH | | | X
PDA requiring surgical treatment | | | X
Rash | | | X
Seizure | | | X
Hyperbilirubinemia requiring exchange transfusion | | | X
Neutropenia requiring granulocyte colony stimulating factor (G-CSF) | | | X
Renal failure requiring hemodialysis | | | X
Laboratory Values
AST | | X | X | X
ALT | | X | X | X
Gamma-glutamyl transpeptidase (GGT) | | X | X | X
Direct bilirubin | | X | X | X
White Blood Cell (WBC) count | | X | X | X
Neutrophil count | | X | X | X
Hematocrit | | X | X | X
Platelets | | X | X | X
BUN | | X | X | X
Creatinine | | X | X | X
Glucose | | X | X | X
Sodium | | X | X | X
Potassium | | X | X | X
Microbiology Results
Viral culture (Blood, CSF, conjunctivae, mouth, naso/oropharynx, urine, rectum, stool or skin or mucous membrane lesions) (organism) | X | X | X
HSV DNA PCR (Blood, CSF, conjunctivae, mouth, naso/oropharynx, urine, rectum, stool or skin or mucous membrane lesions) | X | X | X
HSV direct immunofluorescence assay from swabs or scrapings of skin or mucous membrane lesions | X | X | X
Acyclovir
Days of administration | | | X

### 9.1.2 Medical Chart Review

Infants with confirmed or suspected HSV in ▬▬▬▬▬ were identified to evaluate safety of HD acyclovir. Medical records of approximately 60 infants with confirmed or suspected HSV who received IV acyclovir per standard of care between 2002 and 2014 at 4 sites were anticipated to be included in the analysis.

Data on subject demographics, clinical characteristics, acyclovir administration, AEs, laboratory and microbiology results were extracted as shown in Table 9-2.

Table 9-2 Variables Collected From the Medical Records

| Day of birth | Days −1 to −3 | On acyclovir | Days +1 to +3 | Discharge
Demographics
Gender | X
Birth year | X
Date of admission | X
Discharge date | | | | | X
Gestational age | X
Postnatal age | | | X
Birth weight | X
Race/ethnicity | X
Inborn/outborn | X
Mode of delivery | X
Adverse Events
Hypotension requiring pressors | | | X
Medical NEC | | | X
Surgical NEC | | | X
Spontaneous intestinal perforation | | | X
Grade II IVH | | | X
Grade III or IV IVH | | | X
PDA requiring surgical treatment | | | X
Rash generalized and localized (excluding diaper rash) | | | X
Seizure (diagnosis assigned in the medical chart, no need for electroencephalogram confirmation) | | | X
Hyperbilirubinemia requiring exchange transfusion | | | X
Neutropenia requiring G-CSF | | | X
Renal failure requiring hemodialysis | | | X
Laboratory Values
AST | | X | X | X
ALT | | X | X | X
GGT | | X | X | X
Direct bilirubin | | X | X | X
WBC count | | X | X | X
Neutrophil count | | X | X | X
Hematocrit | | X | X | X
Platelets | | X | X | X
BUN | | X | X | X
Creatinine | | X | X | X
Glucose | | X | X | X
Sodium | | X | X | X
Potassium | | X | X | X
Microbiology results
Viral culture (Blood, CSF, conjunctivae, mouth, naso/oropharynx, urine, rectum, stool or skin or mucous membrane lesions) (organism) | X | X | X
HSV DNA PCR (Blood, CSF, conjunctivae, mouth, naso/oropharynx, urine, rectum, stool or skin or mucous membrane lesions) | X | X | X | X
HSV direct immunofluorescence assay from swabs or scrapings of skin or mucous membrane lesions | X | X | X | X
Acyclovir^*^
Date time of start/stop therapy | | | X
Dose amount/interval | | | X
Dosing weight | | | X
Current weight | | | X

* Every change in acyclovir dosing/frequency associated was recorded

## 9.2 Discussion of Study Design and Choice of Control Groups

Not applicable.

## 9.3 Selection of Study Population

### 9.3.1 Inclusion Criteria

#### PMG administrative database review

1. Discharged from an intensive care nursery managed by the PMG from 2002 to 2012 (Discharged status include discharged home, discharged to another hospital, or death).
2. Neonatal HSV infection defined as ≥1 of the following features:
  - Positive HSV DNA PCR in ≥1 sites:
    - Blood
    - CSF
    - Skin, mouth, naso/oropharynx, conjunctivae, urine, stool or rectum obtained ≥24 hours after birth
    - From swabs or scrapings of skin or mucous membrane lesions
  - Positive HSV culture in ≥1 sites:
    - Blood
    - CSF
    - Skin, mouth, naso/oropharynx, conjunctivae, urine, stool or rectum obtained ≥24 hours after birth
  - Positive HSV direct immunofluorescence assay from swabs or scrapings of skin or mucous membrane lesions
  - Clinical diagnosis of HSV
3. ≥14 days of acyclovir therapy unless the infant died prior to Day 14 of therapy. (This criterion was expanded to ≥14 days to increase the study sample size.)
4. <120 days of age at 1^st^ dose of acyclovir.

#### Medical Chart Review

1. HSV infection defined as ≥1 of the following features:
  - Positive HSV DNA PCR in ≥1 sites:
    - Blood
    - CSF
    - Skin, mouth, naso/oropharynx, conjunctivae, urine, stool or rectum obtained ≥24 hours after birth
    - From swabs or scrapings of skin or mucous membrane lesions
  - Positive HSV culture in ≥1 sites:
    - Blood
    - CSF
    - Skin, mouth, naso/oropharynx, conjunctivae, urine, stool or rectum obtained ≥24 hours after birth
  - Clinical Diagnosis of HSV
2. ≥21 days of acyclovir therapy unless the infant died prior to Day 21 of therapy
3. <120 days of age at 1^st^ dose.

### 9.3.2 Exclusion Criteria

No exclusion criteria were listed for the PMG database and Medical Chart Review components of this study. Exclusion criteria were not addressed in the Whitley and Kimberlin publications.

## 9.4 Treatments

The drug of interest in this study was acyclovir; however, no acyclovir was administered as part of this study.

### 9.4.1 Prior and Concomitant Therapy

No concomitant medications or treatments were administered in this protocol. Data on concomitant medications were not extracted from the PMG database or medical charts.

### 9.4.2 Treatment Compliance

Not applicable.

## 9.5 Efficacy and Safety Variables

No efficacy variables were assessed in either the medical chart review or Pediatrix database review.

### Medical Chart Review

Safety variables include diagnosis adverse events, laboratory adverse events and positive HSV diagnostic tests.

### Pediatrix Administrative Database Review

Safety variables include diagnosis adverse events and laboratory adverse events.

## 9.6 Data Quality Assurance

For the Medical Chart Review, the principal investigator (PI) provided direct access to all trial-related sites, source data/documents, data collection forms, and reports for the purpose of monitoring and auditing by the sponsor, and inspection by local and regulatory authorities. The PI ensured that all study personnel were appropriately trained and applicable documentations were maintained on site. The BPCA DCC implemented quality control procedures beginning with the data entry system and generate data quality control checks that were run on the database. Any missing data or data anomalies were communicated for prompt clarification and resolution.

## 9.7 Statistical Methods and Determination of Sample Size

### 9.7.1 Sample Size

#### Pediatrix Medical Group Database

In the PMG database, 368 infants met the inclusion criteria from 2002 to 2012. This sample size provided for reasonable estimates and 95% confidence interval (CI) for safety. If 1% of the infants had an AE, then the 95% CI (exact binomial) for that AE within the participant population was 0.3 to 2.8%.

#### Medical Chart Review

Forty-nine infants were included in the analyses. Data were collected in reverse chronological order, starting with the most recent data available until the desired sample size was reached. The actual sample size of 49 provided for a reasonable estimate for safety. If one infant had an AE, the 95% CI (exact binomial) for that AE within the participant population was 0.01 to 10.9%.

### 9.7.2 Analysis Populations

For the Medical Chart Review, the safety population included all eligible participants with retrospective data recorded in the electronic data capture (EDC) system. This population was used for all analyses. In addition, several participants who received <21 days of recorded IV acyclovir therapy at the study sites and did not die were entered into the EDC system. These participants are also included in the safety analyses. A discussion of these participants is included in Section 10.2.

For the PMG database review, participants who met the eligibility criteria in Section 9.3.1 were included in the analysis. The definition of HSV used to determine eligibility is discussed in the analysis report in Appendix 16.4.1.

### 9.7.3 General Statistical Methodology

For the PMG database and Medical Chart Review analyses, descriptive analysis was used to examine the frequency of diagnosis adverse events and laboratory adverse events. Frequency of adverse events was analyzed at both the participant level (diagnosis) and the participant-day level (laboratory AE). The number and percentage of participants who experienced an event and the total number of events were summarized. Analyses in this study are exploratory or descriptive in nature.

For the Medical Chart Review analysis, clinical characteristics are summarized by whether the participant had an event. Participant-level descriptive summaries of gender, race/ethnicity, and key endpoints are presented as shown in Table 9-3 by age group and site. Age groups were selected to reflect enrollment groups used in the PTN acyclovir PK study (NCT00942084).

Table 9-3 Age Groups

Group | Gestational Age | Postnatal Age
1 | 23-29 weeks | All
2 | 30-34 weeks | All
3 | 35-42 weeks | <14 days
4 | 35-42 weeks | >=14 days

### 9.7.4 Definition of Diagnosis and Laboratory Adverse Events

The same AE definitions were used to analyze the PMG database and medical charts. Dose response analyses were only performed for data from the medical chart review.

Diagnosis AE – A diagnosis AE was attributed to acyclovir if it presented on a day that the infant was exposed to acyclovir.

Laboratory AE – A laboratory AE was attributed to acyclovir if it presented on a day that the infant was exposed to acyclovir.

AEs reported on days in which acyclovir was not dosed or dosed through oral/enteral route, including AEs reported before the first day of documented IV acyclovir dosing, were not included in any analysis for the medical chart review analysis. Administration route was not available in the PMG database.

The evaluation of safety was based upon the diagnosis or laboratory values of special interest listed in Table 9-4, which was adapted from Appendices A and B in the protocol. All events occurring on or after the first day of IV acyclovir dosing and on a day that participants were exposed to IV acyclovir were included in the safety analyses. For all diagnosis and laboratory endpoints dose response summaries were analyzed as discussed in Section 9.7.6 and 9.7.7, respectively. Participants with evaluations recorded as not done were treated as missing data.

Table 9-4 Diagnoses and Laboratory Values of Special Interest

Events of Special Interest – Diagnosis
Mortality
Gastrointestinal
Neurologic
Cardiovascular
Hematologic
Nephrology
Dermatologic
Events of Special Interest – Laboratory Values
Serum electrolytes: Hyperglycemia, Hypoglycemia, Hypernatremia, Hyponatremia, Hyperkalemia, Hypokalemia,
Renal dysfunction: Elevated BUN, Elevated creatinine
Liver dysfunction: Elevated AST, Elevated ALT, Elevated GGT, Direct Bilirubin
Complete blood count: Leukocytosis, Leukopenia, Neutropenia, Thrombocytopenia, Thrombocytosis

#### Endpoint Description

The diagnosis adverse events of interest are listed in Table 9-5, and include gastrointestinal events with medical/surgical necrotizing enterocolitis (NEC) or spontaneous intestinal perforation; neurologic events with grade II or above intraventricular hemorrhage (IVH) or seizure; cardiovascular events with hypotension requiring pressors or PDA requiring surgical treatment; hematologic events with neutropenia requiring granulocyte-colony stimulating factor (G-CSF) or hyperbilirubinemia requiring exchange transfusion; nephrology events with renal failure requiring hemodialysis and dermatologic events with rash (systemic and localized excluding diaper rash).

Table 9-5 Diagnosis AEs of Interest

Body System | Mild Event | Severe Event
Gastrointestinal | Medical NEC | Surgical NEC; Spontaneous intestinal perforation
Neurologic | Grade II IVH | Grade III or IV IVH; Seizure
Cardiovascular | Hypotension requiring pressors | PDA requiring surgical treatment
Hematologic | | Neutropenia requiring G-CSF; Hyperbilirubinemia requiring exchange transfusion
Nephrology | | Renal failure requiring hemodialysis
Dermatologic | Rash (systemic and localized)

The laboratory adverse events of interest are listed in Table 9-6. Any laboratory values indicating abnormal serum electrolytes, renal dysfunction, liver dysfunction or abnormal complete blood count were captured as laboratory adverse events of interest.

Table 9-6 Laboratory AEs of Interest

Laboratory Values | Mild Event | Severe Event
Serum electrolytes
Hyperglycemia(Glucose) | >150 mg/dL | >400 mg/dL
Hypoglycemia(Glucose) | <40 mg/dL | <20 mg/dL
Hypernatremia (Sodium) | >150 mmol/L | >160 mmol/L
Hyponatremia (Sodium) | <125 mmol/L | <115 mmol/L
Hyperkalemia(Potassium) | >6.5 mmol/L | >8.0 mmol/L
Hypokalemia(Potassium) | <3.0 mmol/L | <2.0 mmol/L
Renal dysfunction
Elevated BUN | >60 mg/dL | >100 mg/dL
Elevated creatinine | >1.7 mg/dL | >3.0 mg/dL
Liver dysfunction
Elevated AST | >400 U/L | >1000 U/L
Elevated ALT | >200 U/L | >1000 U/L
Elevated GGT | >100 U/L | >200 U/L
Direct bilirubin | >3 mg/dL | >10 mg/dL
Complete blood count
Leukocytosis (WBC) | >40,000/mm^3^ | >100,000/mm^3^
Leukopenia (WBC) | <5000/mm^3^ | <2000/mm^3^
Neutropenia (Neutrophils) | <500/mm^3^ | <100/mm^3^
Thrombocytopenia (Platelets) | <100,000/mm^3^ | <20,000/mm^3^
Thrombocytosis (Platelets) | >600,000/mm^3^ | >1,200,000/mm^3^

### 9.7.5 Statistical Issues for Analyses of Events of Special Interest

In the Medical Chart Review, analysis of AEs by severity, AEs are summarized by participant using the greatest level of severity. In Section 12 and 14 text and tables for medical chart review AEs, AEs are reported as mild if the reported values met the threshold for a mild event but did not meet the threshold for a severe event. AEs that met the threshold for a severe event are only counted in the severe category. For the medical chart review analysis, the “events per day” in the summary is defined as number of days with an event/total number of dosing days across all participants. If a laboratory event occurred multiple times on the same day during the study, these events were considered as different events in the summary of events per day.

Among participants in the Medical Chart Review, the maximal daily and total doses are summarized via tables and the relationship of AEs to daily dose and cumulative dose are also presented in this final report. Sections 9.7.6 and 9.7.7 describe dose response analyses in more detail.

### 9.7.6 Dose Response Analyses of Diagnosis Adverse Events (Medical Chart Review)

Dose-response analyses of diagnosis AEs was at the participant level and primarily used calculated cumulative, current and maximum daily dose at the time of the first event or diagnosis reported on a day of IV acyclovir dosing. The analyses were based on descriptive summaries for each diagnosis AE. The GA and PNA group, gender, calculated cumulative dose, maximum dose and current daily dose were summarized for each event by whether the event occurred or did not occur on a day of IV acyclovir dosing. Analyses include all IV doses received until the end of the event day.

### 9.7.7 Dose Response Analyses of Clinical Laboratory Endpoints (Medical Chart Review)

Analyses of clinical laboratory endpoints was at the participant level and performed using descriptive summaries of the events. The GA and PNA group, gender, calculated cumulative dose, maximum dose and current daily dose were summarized for each event by whether the event occurred or did not occur on a day of IV acyclovir dosing. If a laboratory event occurred multiple times at different severity levels during the study in the same participant, the first occurrence of the most severe event was used in the dose response analysis for that participant. Analyses include all IV doses received until the end of the event day.

### 9.7.8 Analyses of HSV Diagnostic Tests (Medical Chart Review)

Type and findings of positive HSV diagnostic tests performed at baseline (all positive HSV diagnostic tests collected on or before the first day of recorded IV acyclovir dosing) and the end of study (last recorded positive HSV diagnostic tests after the first day of recorded IV acyclovir dosing) were summarized by GA and PNA group and by site. The total number of participants with positive HSV diagnostic tests was also presented at both time points.

### 9.7.9 Handling of Dosing Data from Medical Chart Review

Missing dosing period start or stop times, dose amounts and dosing weights were imputed in the analyses. Missing dose times were imputed as 12:00 PM on the dosing date. The missing values for dose amount and dose weight were imputed using the last observation carried forward.

The dose date/time was derived based upon dose frequency and status (start, change and end) from the start of dose date/time to the end of dose date/time. The rule used to calculate the number of doses is as follows:

1. The non-integer dose number for “Change” doses was rounded down:
  - e.g., If dose number was 3.8 from start until change of dose, 3 doses were counted.
2. The non-integer dose number for “End” dose was considered to use 0.7 rule as cutoff:
  - e.g., If dose number was 3.8 from start until end of dose, 4 doses were counted. If dose number was 3.4 from start until end of dose, 3 doses were counted.

## 9.8 Changes in the Conduct of the Study or the Planned Analyses

### 9.8.1 Changes in Conduct of the Study

The Medical Chart Review in this study was expanded to include infants born through 2014, and infants with suspected HSV in amendments to protocol v3.0 and v4.0. The title of the protocol was changed in protocol version 4.0. Only 2 sites, ▬▬▬▬▬ were selected to institute these protocol versions.

### 9.8.2 Changes in Planned Analyses

For the Medical Chart Review, only IV acyclovir dosing records were included in the analyses. IV acyclovir dosing records after the first oral/enteral dose were removed from the analyses.

The first presentation of diagnosis AEs cannot be assessed sufficiently in our data system due to unknown diagnosis information before the start of recorded acyclovir dosing, so only diagnosis AEs received on the day of IV acyclovir dosing will be included in the analyses.

Inclusion criteria for the PMG Database review was expanded to include infants at ≥14 days (from ≥21 days) of acyclovir therapy unless the infant died prior to Day 14 (previously Day 21) of therapy.

The safety population for the Medical Chart Review analysis was expanded to include infants receiving <21 days of acyclovir therapy during the hospitalization and did not die who were entered in the EDC system. Only dosing data recorded in the EDC for these participants are included in the dose response analyses.

As discussed in Section 7.2, additional efficacy and safety analyses of the Whitley et al. (Section 7.1.3.1) and Kimberlin et al. (Section 7.1.3.2) prospective studies were not performed.