# 8 STUDY OBJECTIVES

The purpose of this study was to evaluate the safety and efficacy of IV acyclovir in infants with HSV or suspected HSV.

Primary objectives were to:

1. Characterize the safety of HD acyclovir
2. Characterize therapeutic efficacy of HD acyclovir