# 7 INTRODUCTION

The Best Pharmaceuticals for Children Act (BPCA) mandates the NIH to prioritize therapeutic areas in critical need for pediatric labeling, sponsor pediatric clinical trials, and submit these data to FDA for consideration for labeling changes. This study was conducted in accordance with Section 409I of the Public Health Service Act; as such, the results from this research are being submitted to FDA for review and possibly negotiating a labeling change. This research study was contractually supported by the National Institute of Child Health and Human Development (NICHD). The NICHD awarded a contract to the Duke Clinical Research Institute (DCRI) to establish a Pediatric Trials Network (PTN) in order to facilitate trial design for studies supported by NIH. A separate contract was awarded to The Emmes Corporation to serve as the BPCA Data Coordinating Center (DCC).

Neonatal herpes simplex virus (HSV) occurs in 1 in 3,000 births in the U.S. (1,000-1,500 infants/year) [1,2]. Neonatal HSV most often results from exposure at delivery and can manifest as 1) disseminated disease (25%); 2) central nervous system (CNS) disease (30%); or 3) skin, eye, mouth (SEM) disease (45%) [3]. Untreated neonatal HSV carries 60% to 80% mortality. Institution of high-dose (60 mg/kg/day) intravenous (IV) acyclovir therapy for 21 days has potentially reduced neonatal HSV mortality from 57% to 31% for disseminated disease and from 20% to between 6% and 14% for CNS disease [4]. Although acyclovir has reduced mortality dramatically, morbidity remains high. Survivors often suffer from HSV cutaneous recurrences (41%) [5], and infants with disseminated or CNS disease are at high risk of long-term neurodevelopmental impairment (NDI). Neurologic sequela occurs in 20% to 86% of cases without oral suppressive therapy [4]. Long term complications can manifest as microcephaly, hydrocephalus, encephalomalacia, spasticity, paresis, blindness, deafness, or seizures [6–8].

Acyclovir is a nucleoside analog of guanine, that lacks a 3’ hydroxyl group on its side chain. The drug is phosphorylated to acyclo-GMP by the viral thymidine kinase 3000-fold more efficiently than cellular thymidine kinase. The phosphorylated drug is then incorporated into a nascent deoxyribonucleic acid (DNA) sequence by DNA polymerase which terminates replication. Acyclo-GTP has 100 times higher affinity for viral DNA polymerase than cellular DNA polymerase.

The primary toxicities associated with acyclovir are neutropenia, nephrotoxicity and neurotoxicity. In a prospective trial, neutropenia occurred in 21% of infants with localized disease (CNS or SEM) treated with a high dose (HD) of acyclovir (60 mg/kg/day) [4]. The majority of these patients had absolute neutrophil counts (ANCs) between 500/mm^3^ and 1000/mm^3^. Neutropenia resolved either during continuation of HD acyclovir or after its cessation. Secondly, acyclovir’s potential nephrotoxicity is well described in the literature. In Kimberlin et al study, 4 of 64 HD acyclovir recipients (6%) developed grade 3 or 4 toxicity [4]. All 4 of these recipients had disseminated HSV disease, which could either contribute to or account for this toxicity. Neurotoxicity can include seizures and lightheadedness [9,10].

Acyclovir was well tolerated in an open-label PTN study of 32 infants recently completed (“An Open Label Study to Describe the Pharmacokinetics of Acyclovir in Premature Infants”; Investigational New Drug application [IND] # 106,153) [11]. The cohort represented a group of critically ill infants. Overall, 38 adverse events (AEs) were reported in 66% of the participants. The most frequently reported AEs were adrenal insufficiency (3 participants, 9%) and patent ductus arteriosus (3 participants, 9%). The proportion of infants with AEs was highest, (90%), among infants with a postnatal age (PNA) <14 days and gestational age (GA) of 23 to 29 weeks. Only 1 AE was considered related to study drug (worsening serum creatinine). A total of 4 serious adverse events (SAEs) were reported in 4 infants (13%). The proportion of infants with SAEs was higher for infants 35 to 41 weeks gestation (38%). Two of the SAEs were infant deaths. None of the SAEs were determined to be related to study drug. One death was due to a diagnosis of nonketotic hyperglycinaemia and one was due to sepsis.

Acyclovir is primarily excreted renally through a combination of glomerular filtration and tubular secretion. Thus clearance and half-life are dependent on renal function [12]. In the infant, a statistically significant relationship was demonstrated between clearance (CL) and serum creatinine [10]. Reported acyclovir half-life (t_1/2_) in infants with normal serum creatinine level ranged from 3.8 to 5.0 hours [10,12]. Acyclovir pharmacokinetics (PK) in full term infants was consistent with previous reports from studies of adults [13]. Acyclovir levels in cerebrospinal fluid (CSF) are approximately 30 to 70% of corresponding plasma levels [14–17]. Once steady-state levels are attained, CSF concentrations vary little [16].

In the trial cited above (IND# 106,153), a population PK model was developed based using plasma samples from 28 infants [11]. Postmenstrual age (PMA) was significantly associated with acyclovir CL [11]. No covariates other than weight were associated with volume of distribution (V). The final model was: CL (L/h/kg) =0.305 * (PMA/31.3)^3.02^; V (L/kg) = 2.8. The between participant variability for CL and V were 53% and 85%, respectively. A new dosing strategy based on PMA was developed to account for developmental changes in acyclovir disposition.

## Pharmacodynamics Endpoint

In the PTN acyclovir PK study (National Clinical Trials [NCT] 00942084), target acyclovir systemic exposures were simulated with the following dosing regimen [11]:

- 20 mg/kg every 12 hours in infants <30 weeks PMA
- 20 mg/kg every 8 hours in infants 30 to <36 weeks PMA
- 20 mg/kg every 6 hours in infants 36 to 41 weeks PMA

Acyclovir systemic exposures in infants were similar to observed adult exposures, and the surrogate pharmacodynamic (PD) target (steady state concentrations for 50% of dosing interval ≥3 mg/L) was achieved in 91% of infants ≤41 weeks PMA.

Previous studies have suggested that efficacy of acyclovir is dependent upon the time above the 50% inhibitory concentration (IC_50_) for the viral strain being treated [18]. A PD target consisting of trough concentration (Cmin_ss_) ≥3 mg/L has been previously described [19]. This PD target was chosen based on the HSV IC_50_ (1 mg/L) and reported acyclovir CNS penetration of approximately 30% to 50% [15, 20].

## 7.1 Data Sources for This Report

### 7.1.1 Pediatrix Medical Group

Records from the Pediatrix Medical Group (PMG) administrative database were reviewed for this report. The PMG database is prospectively created from electronic health records of infants admitted to >300 neonatal intensive care units (NICUs) in the US. It is one of the largest repositories of data for neonatal medicine. The database includes approximately 20% of all NICU patients in the US and >90,000 NICU admissions annually. Administration route was not available in the PMG database. Methodology and results for the PMG analysis are described in Section 9 through 13 of this report. A more detailed description of study procedure, analysis of the Pediatrix database, and results are provided in Appendix 16.4.1. Additional description of the database is provided in Appendix 16.4.2.

### 7.1.2 Medical Chart Review

Medical records provided by ▬▬▬▬▬l were used to evaluate the safety of intravenous HD acyclovir (60 mg/kg/day).

### 7.1.3 Major Clinical Trials of Acyclovir Efficacy in Neonatal Herpes Simplex Virus Infection

#### 7.1.3.1 Whitley et al. [8]

This multi-center blinded randomized (1:1) control trial compared standard dose (SD) acyclovir (30 mg/kg/day) versus 30 mg/kg/day of vidarabine for 10 days in the management of neonatal herpes simplex virus infection. In that study, 202 infants with virologically confirmed infection were enrolled and followed up at 12 months of age. After adjustment for the extent of disease, the 2 regimens were deemed similar for morbidity and mortality. However, the study lacked statistical power to determine differences in outcome within each subgroup of localized HSV, encephalitis and disseminated infection. The publication is provided in Appendix 16.1.11.

#### 7.1.3.2 Kimberlin et al. [4]

This study was an open-label evaluation of acyclovir for 21 days. A total of 88 infants who had been diagnosed with HSV infection were enrolled including 16 who received an intermediate dose (ID) (45 mg/kg/day) and 72 who received HD (60 mg/kg/day). Among those, 79 infants with virologically confirmed infection were included in the efficacy analysis. Clinical outcomes (neurodevelopment impairment, mortality and HSV recurrences) were assessed at up to 4 years of life. In infants with virologically confirmed infection and who received HD acyclovir (n=66), outcomes at 12 months of age were compared with the historical cohort who received SD acyclovir from the Whitley trial. The survival rate for infants treated with HD acyclovir was statistically significantly higher than for those treated with SD acyclovir (Odds Ratio: 3.3; 95% CI: 1.5 to 7.3). Recipients of HD acyclovir had a borderline significant decrease in morbidity compared with SD recipients, after adjusting for the extent of disease (SEM vs. CNS vs. disseminated), HSV type (1 vs. 2), prematurity, and disease severity (seizures). The publication is provided in Appendix 16.1.11.

## 7.2 Structure for this Clinical Study Report

This clinical study report analyzes and discusses data derived from the PMG database (Section 7.1.1) and a medical chart review conducted at 4 clinical sites (Section 7.1.2). Data from the Whitley et al. (Section 7.1.3.1) and Kimberlin et al. (Section 7.1.3.2) prospective studies were unavailable; therefore, the analyses for efficacy and safety originally planned to be conducted as part of the protocol were not performed. The published manuscripts from both studies are provided in Section 16.1.11. Sections 9 and 10 of this report covers the investigational plan, and overall study population, respectively. Section 11, reserved for efficacy, is no longer applicable to this study. Section 12 provides the safety evaluation from all available data sources. Section 13 contains conclusions reached from the analyses of the data.