# 6 INVESTIGATOR AND STUDY ADMINISTRATIVE STRUCTURE

## 6.1 Principal Investigator

The medical chart review study was initiated at four sites in the United States. A list of investigators is provided in Appendix 16.1.4.

## 6.2 Administrative Structure

The following is a list of organizations critical to the conduct of the study:

IND SPONSOR and PRINCIPAL INVESTIGATOR | P. Brian Smith, MD, MPH, MHS; Professor of Pediatrics; Duke University Medical Center; Duke Clinical Research Institute; 2400 Pratt St.; Durham, NC 27715; ▬▬▬▬▬
FUNDING SPONSOR | David Siegel, MD; The Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD); National Institutes of Health; 6710B Rockledge Drive ▬, ▬; Bethesda, MD 20892; ▬▬▬▬▬
CONTRACT RESEARCH ORGANIZATION; Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | The Emmes Corporation (BPCA DCC); 401 N. Washington Street, Suite 700; Rockville, MD 20850; ▬▬▬▬▬; PI:▬ PhD; ▬; Project Director: ▬; ▬