# 15 REFERENCE LIST

1 Flagg EW, Weinstock H. Incidence of neonatal herpes simplex virus infections in the United States, 2006. Pediatrics. 2011;127(1):e1–8.21149432
2 Brown ZA, Benedetti J, Ashley R, . Neonatal herpes simplex virus infection in relation to asymptomatic maternal infection at the time of labor. N Engl J Med. 1991;324(18):1247–1252.1849612
3 Kimberlin DW, Lin CY, Jacobs RF, . Natural history of neonatal herpes simplex virus infections in the acyclovir era. Pediatrics. 2001;108(2):223–229.11483781
4 Kimberlin DW, Lin CY, Jacobs RF, . Safety and efficacy of high-dose intravenous acyclovir in the management of neonatal herpes simplex virus infections. Pediatrics. 2001;108(2):230–238.11483782
5 Kimura H, Futamura M, Ito Y, . Relapse of neonatal herpes simplex virus infection. Arch Dis Child Fetal Neonatal Ed. 2003;88(6):F483–F4866.14602695
6 Malm G, Forsgren M, el Azazi M, Persson A. A follow-up study of children with neonatal herpes simplex virus infections with particular regard to late nervous disturbances. Acta Paediatr Scand. 1991;80(2):226–234.1709771
7 Tiffany KF, Benjamin DK, Jr., Palasanthiran P, O’Donnell K, Gutman LT. Improved neurodevelopmental outcomes following long-term high-dose oral acyclovir therapy in infants with central nervous system and disseminated herpes simplex disease. J Perinatol. 2005;25(3):156–161.15605069
8 Whitley R, Arvin A, Prober C, .; Infectious Diseases Collaborative Antiviral Study Group. A controlled trial comparing vidarabine with acyclovir in neonatal herpes simplex virus infection. N Engl J Med. 1991;324(7):444–449.1988829
9 Rashiq S, Briewa L, Mooney M, Giancarlo T, Khatib R, Wilson FM. Distinguishing acyclovir neurotoxicity from encephalomyelitis. J Intern Med. 1993;234(5):507–511.8228796
10 Englund JA, Fletcher CV, Balfour HH, Jr. Acyclovir therapy in neonates. J Pediatr. 1991;119(1 Pt 1):129–135.2066845
11 Sampson MR, Bloom BT, Lenfestey RW, . Population pharmacokinetics of intravenous acyclovir in preterm and term infants. Pediatr Infect Dis J. 2014;33(1):42–49.24346595
12 Lietman PS. Acyclovir clinical pharmacology: an overview. Am J Med. 1982;73(1A):193–196.7048912
13 Hintz M, Connor JD, Spector SA, Blum MR, Keeney RE, Yeager AS. Neonatal acyclovir pharmacokinetics in patients with herpes virus infections. Am J Med. 1982;73(1A):210–214.6285713
14 Yeager AS. Use of acyclovir in premature and term neonates. Am J Med. 1982;73(1A):205–209.
15 Blum MR, Liao SH, de Miranda P. Overview of acyclovir pharmacokinetic disposition in adults and children. Am J Med. 1982;73(1A):186–192.7048911
16 Lycke J, Andersen O, Svennerholm B, Appelgren L, Dahlof C. Acyclovir concentrations in serum and cerebrospinal fluid at steady state. J Antimicrob Chemother. 1989;24(6):947–954.2621178
17 O’Brien JJ, Campoli-Richards DM. Acyclovir: an updated review of its antiviral activity, pharmacokinetic properties and therapeutic efficacy. Drugs. 1989;37(3):233–309.2653790
18 Saiag P, Praindhui D, Chastang C; Genival Study Group. A double-blind, randomized study assessing the equivalence of valacyclovir 1000 mg once daily versus 500 mg twice daily in the episodic treatment of recurrent genital herpes. J Antimicrob Chemother. 1999;44(4):525–531.10588314
19 Brigden D, Rosling AE, Woods NC. Renal function after acyclovir intravenous injection. Am J Med. 1982;73(1A):182–185.6285711
20 Rabalais GP, Nusinoff-Lehrman S, Arvin AM, Levin MJ. Antiviral susceptibilities of herpes simplex virus isolates from infants with recurrent mucocutaneous lesions after neonatal infection. Pediatr Infect Dis J. 1989;8(4):221–223.2541398