# 14 TABLES, FIGURES, AND GRAPHS REFERRED TO BUT NOT INCLUDED IN THE TEXT

## 14.1 Demographic Data

Table Number | Population | Table Title / Summary
14.1.1 | Safety Population | Summary of Baseline Demographics by GA and PNA Group
14.1.2 | Safety Population | Summary of Baseline Demographics by Site

## 14.2 Safety Data

Table Number | Population | Table Title / Summary
14.2.1.1.1 | Safety Population | Summary of Diagnosis AEs by GA and PNA Group
14.2.1.1.2 | Safety Population | Summary of Diagnosis AEs by GA, PNA Group and Severity
14.2.1.2.1 | Safety Population | Summary of Diagnosis AEs by Site
14.2.1.2.2 | Safety Population | Summary of Diagnosis AEs by Site and Severity
14.2.1.3.1 | Safety Population | Dose Response Analysis of Diagnosis AEs-Death
14.2.1.3.2 | Safety Population | Dose Response Analysis of Diagnosis AEs-Rash
14.2.1.3.3 | Safety Population | Dose Response Analysis of Diagnosis AEs-Hypotension
14.2.1.3.4 | Safety Population | Dose Response Analysis of Diagnosis AEs-Intraventricular Hemorrhage
14.2.1.3.5 | Safety Population | Dose Response Analysis of Diagnosis AEs-PDA Requiring Surgical Treatment
14.2.1.3.6 | Safety Population | Dose Response Analysis of Diagnosis AEs-Seizure
14.2.1.3.7 | Safety Population | Dose Response Analysis of Diagnosis AEs-Renal Failure
14.2.1.4 | Safety Population | Listing of Participants with CNS, Hepatic or Renal AEs
14.2.2.1.1 | Safety Population | Summary of Laboratory AEs by GA and PNA Group
14.2.2.1.2 | Safety Population | Summary of Laboratory AEs by GA, PNA Group and Severity
14.2.2.2.1 | Safety Population | Summary of Laboratory AEs by Site
14.2.2.2.2 | Safety Population | Summary of Laboratory AEs by Site and Severity
14.2.2.3.1 | Safety Population | Dose Response Analysis of Laboratory AEs-Hyperglycemia
14.2.2.3.2 | Safety Population | Dose Response Analysis of Laboratory AEs-Hypoglycemia
14.2.2.3.3 | Safety Population | Dose Response Analysis of Laboratory AEs-Hypernatrenia
14.2.2.3.4 | Safety Population | Dose Response Analysis of Laboratory AEs-Hyponatremia
14.2.2.3.5 | Safety Population | Dose Response Analysis of Laboratory AEs-Hyperkalemia
14.2.2.3.6 | Safety Population | Dose Response Analysis of Laboratory AEs-Hypokalemia
14.2.2.3.7 | Safety Population | Dose Response Analysis of Laboratory AEs-Elevated BUN
14.2.2.3.8 | Safety Population | Dose Response Analysis of Laboratory AEs-Elevated Creatinine
14.2.2.3.9 | Safety Population | Dose Response Analysis of Laboratory AEs-Elevated ALT
14.2.2.3.10 | Safety Population | Dose Response Analysis of Laboratory AEs-Elevated AST
14.2.2.3.11 | Safety Population | Dose Response Analysis of Laboratory AEs-Elevated Direct Bilirubin
14.2.2.3.12 | Safety Population | Dose Response Analysis of Laboratory AEs-Elevated GGT
14.2.2.3.13 | Safety Population | Dose Response Analysis of Laboratory AEs-Leukocytosis
14.2.2.3.14 | Safety Population | Dose Response Analysis of Laboratory AEs-Leukopenia
14.2.2.3.15 | Safety Population | Dose Response Analysis of Laboratory AEs-Thrombocytosis
14.2.2.3.16 | Safety Population | Dose Response Analysis of Laboratory AEs-Thrombocytopenia
14.2.2.4.1.1 | Safety Population | Summary of Post-baseline Serum Liver Biochemistries Worse-Grade Toxicities by GA and PNA Group
14.2.2.4.1.2 | Safety Population | Summary of Post-baseline Serum Liver Biochemistries Worse-Grade Toxicities by Maximum Dose Group
14.2.2.4.2.1 | Safety Population | Summary of Post-baseline Serum Creatinine Worse-Grade Toxicities by GA and PNA Group
14.2.2.4.2.2 | Safety Population | Summary of Post-baseline Serum Creatinine Worse-Grade Toxicities by Maximum Dose Group
14.2.2.4.3.1 | Safety Population | Summary of Post-baseline Hematology Biochemistries Worse-Grade Toxicities by GA and PNA Group
14.2.2.4.3.2 | Safety Population | Summary of Post-baseline Hematology Biochemistries Worse-Grade Toxicities by Maximum Dose Group
14.2.3.1.1 | Safety Population | Summary of Positive HSV Diagnostic Tests at Baseline by GA and PNA Group
14.2.3.1.2 | Safety Population | Summary of Positive HSV Diagnostic Tests at End of Study by GA and PNA Group
14.2.3.2.1 | Safety Population | Summary of Positive HSV Diagnostic Tests at Baseline by Site
14.2.3.2.2 | Safety Population | Summary of Positive HSV Diagnostic Tests at End of Study by Site

## 14.3 Dosing Data

Table Number | Population | Table Title / Summary
14.3.1.1 | Safety Population | Summary of Study Doses by GA and PNA Group
14.3.1.2 | Safety Population | Summary of Study Doses by Site

Table 14.1.1 Summary of Baseline Demographics by GA and PNA Group Safety Population

| Age Strata | | | | Total; (N=49)
| GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
Postnatal age (Days)
N | 6 | 10 | 25 | 8 | 49
Mean (SD) | 5 (5) | 12 (10) | 7 (2) | 32 (27) | 12 (15)
Median (Min, Max) | 5 (0 - 11) | 9 (0 - 29) | 7 (4 - 12) | 19 (14 - 90) | 8 (0 - 90)
Gestational age (Weeks)
N | 6 | 10 | 25 | 7 | 48
Mean (SD) | 26.8 (2.1) | 32.7 (1.6) | 39.2 (1.6) | 38.7 (1.5) | 36.2 (4.7)
Median (Min, Max) | 27.0 (24.0 - 29.0) | 33.5 (30.0 - 34.0) | 39.0 (35.0 - 41.0) | 39.0 (37.0 - 41.0) | 38.0 (24.0 - 41.0)
Gender
Male | 3 (50.0%) | 5 (50.0%) | 14 (56.0%) | 3 (37.5%) | 25 (51.0%)
Female | 3 (50.0%) | 5 (50.0%) | 11 (44.0%) | 5 (62.5%) | 24 (49.0%)
Ethnicity
Hispanic or Latino | 0 | 0 | 3 (12.0%) | 0 | 3 (6.1%)
Not Hispanic or Latino | 5 (83.3%) | 7 (70.0%) | 18 (72.0%) | 4 (50.0%) | 34 (69.4%)
Not reported | 1 (16.7%) | 3 (30.0%) | 4 (16.0%) | 4 (50.0%) | 12 (24.5%)
Race
White or Caucasian | 3 (50.0%) | 4 (40.0%) | 11 (44.0%) | 3 (37.5%) | 21 (42.9%)
Black or African American | 2 (33.3%) | 4 (40.0%) | 8 (32.0%) | 1 (12.5%) | 15 (30.6%)
Other | 0 | 0 | 1 (4.0%) | 0 | 1 (2.0%)
Not reported | 1 (16.7%) | 2 (20.0%) | 5 (20.0%) | 4 (50.0%) | 12 (24.5%)
Birth weight (Grams)
N | 6 | 10 | 23 | 6 | 45
Mean (SD) | 942 (231) | 1950 (384) | 3416 (440) | 3412 (330) | 2760 (1014)
Median (Min, Max) | 963 (590 - 1215) | 1905 (1400 - 2700) | 3412 (2608 - 4054) | 3514 (2990 - 3782) | 2990 (590 - 4054)
Days in hospital following birth
N | 6 | 6 | 8 | 3 | 23
Mean (SD) | 56 (65) | 26 (16) | 16 (16) | 67 (39) | 36 (41)
Median (Min, Max) | 37 (5 - 182) | 27 (7 - 52) | 10 (2 - 42) | 50 (40 - 112) | 30 (2 - 182)
Inborn
No | 2 (33.3%) | 9 (90.0%) | 21 (84.0%) | 8 (100.0%) | 40 (81.6%)
Yes | 4 (66.7%) | 1 (10.0%) | 4 (16.0%) | 0 | 9 (18.4%)
Mode of delivery
Vaginal | 2 (33.3%) | 8 (80.0%) | 9 (36.0%) | 6 (75.0%) | 25 (51.0%)
Caesarean section | 4 (66.7%) | 2 (20.0%) | 14 (56.0%) | 1 (12.5%) | 21 (42.9%)
Site
CIN | 1 (16.7%) | 2 (20.0%) | 9 (36.0%) | 1 (12.5%) | 13 (26.5%)
▬ | ▬ | ▬ | ▬ | ▬ | ▬
▬ | 4 (66.7%) | 3 (30.0%) | 10 (40.0%) | 3 (37.5%) | 20 (40.8%)
▬ | 0 | 2 (20.0%) | 4 (16.0%) | 1 (12.5%) | 7 (14.3%)

Note: Days in hospital following birth are calculated as (discharge date) – (birth date) + 1 day.

Table 14.1.2 Summary of Baseline Demographics by Site Safety Population

| Site | | | | Total; (N=49)
| ▬; (N=13) | ▬; (N=9) | ▬; (N=20) | ▬; (N=7) | Total; (N=49)
Postnatal age (Days)
N | 13 | 9 | 20 | 7 | 49
Mean (SD) | 9 (5) | 22 (27) | 10 (12) | 10 (7) | 12 (15)
Median (Min, Max) | 8 (0 - 18) | 11 (0 - 90) | 8 (0 - 55) | 8 (4 - 24) | 8 (0 - 90)
Gestational age (Weeks)
N | 13 | 8 | 20 | 7 | 48
Mean (SD) | 37.2 (3.6) | 34.6 (5.4) | 35.9 (5.5) | 37.3 (3.4) | 36.2 (4.7)
Median (Min, Max) | 39.0 (29.0 - 41.0) | 34.5 (25.0 - 41.0) | 38.5 (24.0 - 41.0) | 39.0 (32.0 - 41.0) | 38.0 (24.0 - 41.0)
Gender
Male | 8 (61.5%) | 4 (44.4%) | 11 (55.0%) | 2 (28.6%) | 25 (51.0%)
Female | 5 (38.5%) | 5 (55.6%) | 9 (45.0%) | 5 (71.4%) | 24 (49.0%)
Ethnicity
Hispanic or Latino | 0 | 2 (22.2%) | 0 | 1 (14.3%) | 3 (6.1%)
Not Hispanic or Latino | 13 (100.0%) | 0 | 16 (80.0%) | 5 (71.4%) | 34 (69.4%)
Not reported | 0 | 7 (77.8%) | 4 (20.0%) | 1 (14.3%) | 12 (24.5%)
Race
White or Caucasian | 9 (69.2%) | 1 (11.1%) | 9 (45.0%) | 2 (28.6%) | 21 (42.9%)
Black or African American | 3 (23.1%) | 0 | 8 (40.0%) | 4 (57.1%) | 15 (30.6%)
Other | 0 | 0 | 0 | 1 (14.3%) | 1 (2.0%)
Not reported | 1 (7.7%) | 8 (88.9%) | 3 (15.0%) | 0 | 12 (24.5%)
Birth weight (Grams)
N | 13 | 8 | 17 | 7 | 45
Mean (SD) | 2996 (861) | 2548 (1027) | 2620 (1183) | 2902 (910) | 2760 (1014)
Median (Min, Max) | 3184 (1080 - 4054) | 2815 (822 - 3895) | 2900 (590 - 3915) | 3119 (1620 - 3782) | 2990 (590 - 4054)
Days in hospital following birth
N | 5 | 9 | 6 | 3 | 23
Mean (SD) | 5 (2) | 40 (32) | 62 (60) | 22 (17) | 36 (41)
Median (Min, Max) | 5 (2 - 7) | 40 (12 - 112) | 37 (27 - 182) | 31 (3 - 33) | 30 (2 - 182)
Inborn
No | 13 (100.0%) | 9 (100.0%) | 13 (65.0%) | 5 (71.4%) | 40 (81.6%)
Yes | 0 | 0 | 7 (35.0%) | 2 (28.6%) | 9 (18.4%)
Mode of delivery
Vaginal | 8 (61.5%) | 6 (66.7%) | 7 (35.0%) | 4 (57.1%) | 25 (51.0%)
Caesarean section | 5 (38.5%) | 3 (33.3%) | 10 (50.0%) | 3 (42.9%) | 21 (42.9%)

Note: Days in hospital following birth are calculated as (discharge date) – (birth date) + 1 day.

Table 14.2.1.1.1 Summary of Diagnosis AEs by GA and PNA Group Safety Population

| Age Strata | | | | Total; (N=49)
| GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
Death
Number of Participants | 2 (33.3%) | 2 (20.0%) | 5 (20.0%) | 0 | 9 (18.4%)
Rash
Number of Events | 3 | 6 | 11 | 1 | 21
Number of Participants | 3 (50.0%) | 6 (60.0%) | 8 (32.0%) | 1 (12.5%) | 18 (36.7%)
Hypotension
Number of Events | 3 | 2 | 15 | 0 | 20
Number of Participants | 2 (33.3%) | 2 (20.0%) | 8 (32.0%) | 0 | 12 (24.5%)
Medical NEC
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Surgical NEC
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Spontaneous Intestinal Perforation
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Intraventricular Hemorrhage
Number of Events | 1 | 1 | 0 | 2 | 4
Number of Participants | 1 (16.7%) | 1 (10.0%) | 0 | 2 (25.0%) | 4 (8.2%)
PDA Requiring Surgical Treatment
Number of Participants | 1 (16.7%) | 0 | 0 | 0 | 1 (2.0%)
Seizure
Number of Events | 0 | 2 | 3 | 4 | 9
Number of Participants | 0 | 1 (10.0%) | 3 (12.0%) | 3 (37.5%) | 7 (14.3%)
Hyperbilirubinemia Requiring Exchange Transfusion
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Neutropenia Requiring G-CSF
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Renal Failure
Number of Participants | 0 | 0 | 3 (12.0%) | 0 | 3 (6.1%)

Note: Diagnosis AEs are attributed to acyclovir if they are presented on a day that the participant was exposed to IV acyclovir.

Only diagnosis AEs that occurred after the first day of IV acyclovir dosing are included.

Table 14.2.1.1.2 Summary of Diagnosis AEs by GA, PNA Group and Severity Safety Population

| GA 23-29 weeks; (N=6) | | GA 30-34 weeks; (N=10) | | GA 35-42 weeks; PNA <14 days; (N=25) | | GA 35-42 weeks; PNA >=14 days; (N=8) | | Total; (N=49)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Gastrointestinal
Number of Events | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Neurologic
Number of Events | 0 | 1 | 0 | 3 | 0 | 3 | 0 | 6 | 0 | 13
Number of Participants | 0 | 1 (16.7%) | 0 | 2 (20.0%) | 0 | 3 (12.0%) | 0 | 3 (37.5%) | 0 | 9 (18.4%)
Cardiovascular
Number of Events | 3 | 1 | 2 | 0 | 15 | 0 | 0 | 0 | 20 | 1
Number of Participants | 2 (33.3%) | 1 (16.7%) | 2 (20.0%) | 0 | 8 (32.0%) | 0 | 0 | 0 | 12 (24.5%) | 1 (2.0%)
Hematologic
Number of Events | N/A | 0 | N/A | 0 | N/A | 0 | N/A | 0 | N/A | 0
Number of Participants | N/A | 0 | N/A | 0 | N/A | 0 | N/A | 0 | N/A | 0
Nephrology
Number of Events | N/A | 0 | N/A | 0 | N/A | 3 | N/A | 0 | N/A | 3
Number of Participants | N/A | 0 | N/A | 0 | N/A | 3 (12.0%) | N/A | 0 | N/A | 3 (6.1%)
Dermatologic
Number of Events | 3 | N/A | 6 | N/A | 11 | N/A | 1 | N/A | 21 | N/A
Number of Participants | 3 (50.0%) | N/A | 6 (60.0%) | N/A | 8 (32.0%) | N/A | 1 (12.5%) | N/A | 18 (36.7%) | N/A

Note: Diagnosis AEs are attributed to acyclovir if they are presented on a day that the participant was exposed to IV acyclovir.

Only diagnosis AEs that occurred after the first day of IV acyclovir dosing are included.

N/A represents an event not defined in the protocol.

Table 14.2.1.2.1 Summary of Diagnosis AEs by Site Safety Population

| Site | | | | Total; (N=49)
| ▬; (N=13) | ▬; (N=9) | ▬; (N=20) | ▬; (N=7) | Total; (N=49)
Death
Number of Participants | 6 (46.2%) | 2 (22.2%) | 1 (5.0%) | 0 | 9 (18.4%)
Rash
Number of Events | 3 | 3 | 14 | 1 | 21
Number of Participants | 3 (23.1%) | 3 (33.3%) | 11 (55.0%) | 1 (14.3%) | 18 (36.7%)
Hypotension
Number of Events | 5 | 2 | 10 | 3 | 20
Number of Participants | 5 (38.5%) | 2 (22.2%) | 3 (15.0%) | 2 (28.6%) | 12 (24.5%)
Medical NEC
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Surgical NEC
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Spontaneous Intestinal Perforation
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Intraventricular Hemorrhage
Number of Events | 1 | 3 | 0 | 0 | 4
Number of Participants | 1 (7.7%) | 3 (33.3%) | 0 | 0 | 4 (8.2%)
PDA Requiring Surgical Treatment
Number of Participants | 0 | 0 | 1 (5.0%) | 0 | 1 (2.0%)
Seizure
Number of Events | 2 | 2 | 5 | 0 | 9
Number of Participants | 2 (15.4%) | 2 (22.2%) | 3 (15.0%) | 0 | 7 (14.3%)
Hyperbilirubinemia Requiring Exchange Transfusion
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Neutropenia Requiring G-CSF
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0
Renal Failure
Number of Participants | 0 | 1 (11.1%) | 1 (5.0%) | 1 (14.3%) | 3 (6.1%)

Note: Diagnosis AEs are attributed to acyclovir if they are presented on a day that the participant was exposed to IV acyclovir.

Only diagnosis AEs that occurred after the first day of IV acyclovir dosing are included.

Table 14.2.1.2.2 Summary of Diagnosis AEs by Site and Severity Safety Population

| ▬; (N=13) | | ▬; (N=9) | | ▬; (N=20) | | ▬; (N=7) | | Total; (N=49)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Gastrointestinal
Number of Events | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Neurologic
Number of Events | 0 | 3 | 0 | 5 | 0 | 5 | 0 | 0 | 0 | 13
Number of Participants | 0 | 3 (23.1%) | 0 | 3 (33.3%) | 0 | 3 (15.0%) | 0 | 0 | 0 | 9 (18.4%)
Cardiovascular
Number of Events | 5 | 0 | 2 | 0 | 10 | 1 | 3 | 0 | 20 | 1
Number of Participants | 5 (38.5%) | 0 | 2 (22.2%) | 0 | 3 (15.0%) | 1 (5.0%) | 2 (28.6%) | 0 | 12 (24.5%) | 1 (2.0%)
Hematologic
Number of Events | N/A | 0 | N/A | 0 | N/A | 0 | N/A | 0 | N/A | 0
Number of Participants | N/A | 0 | N/A | 0 | N/A | 0 | N/A | 0 | N/A | 0
Nephrology
Number of Events | N/A | 0 | N/A | 1 | N/A | 1 | N/A | 1 | N/A | 3
Number of Participants | N/A | 0 | N/A | 1 (11.1%) | N/A | 1 (5.0%) | N/A | 1 (14.3%) | N/A | 3 (6.1%)
Dermatologic
Number of Events | 3 | N/A | 3 | N/A | 14 | N/A | 1 | N/A | 21 | N/A
Number of Participants | 3 (23.1%) | N/A | 3 (33.3%) | N/A | 11 (55.0%) | N/A | 1 (14.3%) | N/A | 18 (36.7%) | N/A

Note: Diagnosis AEs are attributed to acyclovir if they are presented on a day that the participant was exposed to IV acyclovir.

Only diagnosis AEs that occurred after the first day of IV acyclovir dosing are included.

N/A represents an event not defined in the protocol.

Table 14.2.1.3.1 Dose Response Analysis of Diagnosis AEs-Death Safety Population

| Lived; (n=40) | Died; (n=9)
GA and PNA Group
GA 23-29 Weeks | 4 (66.7%) | 2 (33.3%)
GA 30-34 Weeks | 8 (80.0%) | 2 (20.0%)
GA 35-42 weeks&PNA <14 days | 20 (80.0%) | 5 (20.0%)
GA 35-42 weeks&PNA >=14 days | 8 (100.0%) | 0
PMA Group
PMA <30 Weeks | 3 (60.0%) | 2 (40.0%)
PMA 30-35 Weeks | 5 (71.4%) | 2 (28.6%)
PMA >35 Weeks | 31 (86.1%) | 5 (13.9%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 18 (75.0%) | 6 (25.0%)
Male | 22 (88.0%) | 3 (12.0%)
Cumulative Dose (mg/kg)^1^
N | 40 | 9
Mean (SD) | 1942 (1515) | 250 (243)
Median (Min, Max) | 1340 (180 - 7178) | 156 (20 - 736)
Maximum Dose (mg/kg/day)^2^
N | 40 | 9
Mean (SD) | 107 (76) | 51 (15)
Median (Min, Max) | 82 (59 - 441) | 60 (20 - 60)
<50 | 0 | 3 (100.0%)
50-70 | 15 (71.4%) | 6 (28.6%)
>70 | 25 (100.0%) | 0
Current Dose (mg/kg/day)^3^
N | N/A | 9
Mean (SD) | N/A | 24 (10)
Median (Min, Max) | N/A | 20 (10 - 40)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 37 (88.1%) | 5 (11.9%)
>1.2 | 3 (50.0%) | 3 (50.0%)
Not Reported | 0 | 1 (100.0%)
Baseline Type of Positive HSV
Blood | 6 (54.5%) | 5 (45.5%)
Cerebrospinal Fluid | 13 (92.9%) | 1 (7.1%)
SEM | 12 (85.7%) | 2 (14.3%)
Unknown | 9 (90.0%) | 1 (10.0%)

Note: Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative IV dose while on study acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily IV dose while on study acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.1.3.2 Dose Response Analysis of Diagnosis AEs-Rash Safety Population

| Participants without Rash; (n=31) | Participants with Rash; (n=18)
GA and PNA Group
GA 23-29 Weeks | 3 (50.0%) | 3 (50.0%)
GA 30-34 Weeks | 4 (40.0%) | 6 (60.0%)
GA 35-42 weeks&PNA <14 days | 17 (68.0%) | 8 (32.0%)
GA 35-42 weeks&PNA >=14 days | 7 (87.5%) | 1 (12.5%)
PMA Group
PMA <30 Weeks | 2 (40.0%) | 3 (60.0%)
PMA 30-35 Weeks | 3 (42.9%) | 4 (57.1%)
PMA >35 Weeks | 25 (69.4%) | 11 (30.6%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 15 (62.5%) | 9 (37.5%)
Male | 16 (64.0%) | 9 (36.0%)
Cumulative Dose (mg/kg)^1^
N | 31 | 18
Mean (SD) | 1350 (1358) | 250 (401)
Median (Min, Max) | 1251 (20 - 6471) | 77 (20 - 1508)
Maximum Dose (mg/kg/day)^2^
N | 31 | 18
Mean (SD) | 85 (72) | 63 (33)
Median (Min, Max) | 61 (20 - 441) | 51 (20 - 121)
<50 | 3 (25.0%) | 9 (75.0%)
50-70 | 16 (84.2%) | 3 (15.8%)
>70 | 12 (66.7%) | 6 (33.3%)
Current Dose (mg/kg/day)^3^
N | N/A | 18
Mean (SD) | N/A | 63 (33)
Median (Min, Max) | N/A | 51 (20 - 121)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 26 (61.9%) | 16 (38.1%)
>1.2 | 4 (66.7%) | 2 (33.3%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 9 (81.8%) | 2 (18.2%)
Cerebrospinal Fluid | 9 (64.3%) | 5 (35.7%)
SEM | 9 (64.3%) | 5 (35.7%)
Unknown | 4 (40.0%) | 6 (60.0%)

Note: Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative IV dose while on study acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily IV dose while on study acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.1.3.3 Dose Response Analysis of Diagnosis AEs-Hypotension Safety Population

| Participants without Hypotension; (n=37) | Participants with Hypotension; (n=12)
GA and PNA Group
GA 23-29 Weeks | 4 (66.7%) | 2 (33.3%)
GA 30-34 Weeks | 8 (80.0%) | 2 (20.0%)
GA 35-42 weeks&PNA <14 days | 17 (68.0%) | 8 (32.0%)
GA 35-42 weeks&PNA >=14 days | 8 (100.0%) | 0
PMA Group
PMA <30 Weeks | 3 (60.0%) | 2 (40.0%)
PMA 30-35 Weeks | 5 (71.4%) | 2 (28.6%)
PMA >35 Weeks | 28 (77.8%) | 8 (22.2%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 18 (75.0%) | 6 (25.0%)
Male | 19 (76.0%) | 6 (24.0%)
Cumulative Dose (mg/kg)^1^
N | 37 | 12
Mean (SD) | 1615 (1088) | 150 (198)
Median (Min, Max) | 1324 (20 - 6471) | 52 (20 - 668)
Maximum Dose (mg/kg/day)^2^
N | 37 | 12
Mean (SD) | 101 (78) | 57 (43)
Median (Min, Max) | 80 (20 - 441) | 50 (20 - 182)
<50 | 3 (33.3%) | 6 (66.7%)
50-70 | 12 (70.6%) | 5 (29.4%)
>70 | 22 (95.7%) | 1 (4.3%)
Current Dose (mg/kg/day)^3^
N | N/A | 12
Mean (SD) | N/A | 51 (44)
Median (Min, Max) | N/A | 40 (20 - 182)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 34 (81.0%) | 8 (19.0%)
>1.2 | 2 (33.3%) | 4 (66.7%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 8 (72.7%) | 3 (27.3%)
Cerebrospinal Fluid | 11 (78.6%) | 3 (21.4%)
SEM | 11 (78.6%) | 3 (21.4%)
Unknown | 7 (70.0%) | 3 (30.0%)

Note: Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative IV dose while on study acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily IV dose while on study acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.1.3.4 Dose Response Analysis of Diagnosis AEs-Intraventricular Hemorrhage Safety Population

| Participants without Intraventricular Hemorrhage; (n=45) | Participants with Intraventricular Hemorrhage; (n=4)
GA and PNA Group
GA 23-29 Weeks | 5 (83.3%) | 1 (16.7%)
GA 30-34 Weeks | 9 (90.0%) | 1 (10.0%)
GA 35-42 weeks&PNA <14 days | 25 (100.0%) | 0
GA 35-42 weeks&PNA >=14 days | 6 (75.0%) | 2 (25.0%)
PMA Group
PMA <30 Weeks | 4 (80.0%) | 1 (20.0%)
PMA 30-35 Weeks | 6 (85.7%) | 1 (14.3%)
PMA >35 Weeks | 35 (97.2%) | 1 (2.8%)
Not Reported | 0 | 1 (100.0%)
Gender
Female | 21 (87.5%) | 3 (12.5%)
Male | 24 (96.0%) | 1 (4.0%)
Cumulative Dose (mg/kg)^1^
N | 45 | 4
Mean (SD) | 1714 (1552) | 135 (106)
Median (Min, Max) | 1319 (20 - 7178) | 110 (39 - 281)
Maximum Dose (mg/kg/day)^2^
N | 45 | 4
Mean (SD) | 100 (75) | 55 (11)
Median (Min, Max) | 80 (20 - 441) | 60 (39 - 60)
<50 | 3 (75.0%) | 1 (25.0%)
50-70 | 17 (85.0%) | 3 (15.0%)
>70 | 25 (100.0%) | 0
Current Dose (mg/kg/day)^3^
N | N/A | 4
Mean (SD) | N/A | 50 (12)
Median (Min, Max) | N/A | 50 (39 - 60)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 38 (90.5%) | 4 (9.5%)
>1.2 | 6 (100.0%) | 0
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 11 (100.0%) | 0
Cerebrospinal Fluid | 12 (85.7%) | 2 (14.3%)
SEM | 13 (92.9%) | 1 (7.1%)
Unknown | 9 (90.0%) | 1 (10.0%)

Note: Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative IV dose while on study acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily IV dose while on study acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.1.3.5 Dose Response Analysis of Diagnosis AEs-PDA Requiring Surgical Treatment Safety Population

| Participants without PDA Requiring Surgical Treatment; (n=48) | Participants with PDA Requiring Surgical Treatment; (n=1)
GA and PNA Group
GA 23-29 Weeks | 5 (83.3%) | 1 (16.7%)
GA 30-34 Weeks | 10 (100.0%) | 0
GA 35-42 weeks&PNA <14 days | 25 (100.0%) | 0
GA 35-42 weeks&PNA >=14 days | 8 (100.0%) | 0
PMA Group
PMA <30 Weeks | 4 (80.0%) | 1 (20.0%)
PMA 30-35 Weeks | 7 (100.0%) | 0
PMA >35 Weeks | 36 (100.0%) | 0
Not Reported | 1 (100.0%) | 0
Gender
Female | 24 (100.0%) | 0
Male | 24 (96.0%) | 1 (4.0%)
Cumulative Dose (mg/kg)^1^
N | 48 | 1
Mean (SD) | 1614 (1532) | 2170
Median (Min, Max) | 1284 (20 - 7178) | 2170
Maximum Dose (mg/kg/day)^2^
N | 48 | 1
Mean (SD) | 94 (71) | 221
Median (Min, Max) | 71 (20 - 441) | 221
<50 | 3 (100.0%) | 0
50-70 | 21 (100.0%) | 0
>70 | 24 (96.0%) | 1 (4.0%)
Current Dose (mg/kg/day)^3^
N | N/A | 1
Mean (SD) | N/A | 18
Median (Min, Max) | N/A | 18
Baseline Serum Creatinine (mg/dL)
<=1.2 | 42 (100.0%) | 0
>1.2 | 5 (83.3%) | 1 (16.7%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 11 (100.0%) | 0
Cerebrospinal Fluid | 14 (100.0%) | 0
SEM | 13 (92.9%) | 1 (7.1%)
Unknown | 10 (100.0%) | 0

Note: Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative IV dose while on study acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily IV dose while on study acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.1.3.6 Dose Response Analysis of Diagnosis AEs-Seizure Safety Population

| Participants without Seizure; (n=42) | Participants with Seizure; (n=7)
GA and PNA Group
GA 23-29 Weeks | 6 (100.0%) | 0
GA 30-34 Weeks | 9 (90.0%) | 1 (10.0%)
GA 35-42 weeks&PNA <14 days | 22 (88.0%) | 3 (12.0%)
GA 35-42 weeks&PNA >=14 days | 5 (62.5%) | 3 (37.5%)
PMA Group
PMA <30 Weeks | 5 (100.0%) | 0
PMA 30-35 Weeks | 6 (85.7%) | 1 (14.3%)
PMA >35 Weeks | 31 (86.1%) | 5 (13.9%)
Not Reported | 0 | 1 (100.0%)
Gender
Female | 21 (87.5%) | 3 (12.5%)
Male | 21 (84.0%) | 4 (16.0%)
Cumulative Dose (mg/kg)^1^
N | 42 | 7
Mean (SD) | 1625 (1510) | 343 (368)
Median (Min, Max) | 1318 (20 - 7178) | 221 (19 - 1027)
Maximum Dose (mg/kg/day)^2^
N | 42 | 7
Mean (SD) | 97 (76) | 68 (41)
Median (Min, Max) | 78 (20 - 441) | 60 (19 - 127)
<50 | 3 (60.0%) | 2 (40.0%)
50-70 | 17 (89.5%) | 2 (10.5%)
>70 | 22 (88.0%) | 3 (12.0%)
Current Dose (mg/kg/day)^3^
N | N/A | 7
Mean (SD) | N/A | 62 (33)
Median (Min, Max) | N/A | 60 (19 - 96)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 37 (88.1%) | 5 (11.9%)
>1.2 | 4 (66.7%) | 2 (33.3%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 9 (81.8%) | 2 (18.2%)
Cerebrospinal Fluid | 12 (85.7%) | 2 (14.3%)
SEM | 13 (92.9%) | 1 (7.1%)
Unknown | 8 (80.0%) | 2 (20.0%)

Note: Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative IV dose while on study acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily IV dose while on study acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.1.3.7 Dose Response Analysis of Diagnosis AEs-Renal Failure Safety Population

| Participants without Renal Failure; (n=46) | Participants with Renal Failure; (n=3)
GA and PNA Group
GA 23-29 Weeks | 6 (100.0%) | 0
GA 30-34 Weeks | 10 (100.0%) | 0
GA 35-42 weeks&PNA <14 days | 22 (88.0%) | 3 (12.0%)
GA 35-42 weeks&PNA >=14 days | 8 (100.0%) | 0
PMA Group
PMA <30 Weeks | 5 (100.0%) | 0
PMA 30-35 Weeks | 7 (100.0%) | 0
PMA >35 Weeks | 33 (91.7%) | 3 (8.3%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 23 (95.8%) | 1 (4.2%)
Male | 23 (92.0%) | 2 (8.0%)
Cumulative Dose (mg/kg)^1^
N | 46 | 3
Mean (SD) | 1704 (1541) | 203 (74)
Median (Min, Max) | 1318 (20 - 7178) | 190 (137 - 283)
Maximum Dose (mg/kg/day)^2^
N | 46 | 3
Mean (SD) | 99 (74) | 60 (1)
Median (Min, Max) | 80 (20 - 441) | 60 (60 - 61)
<50 | 3 (100.0%) | 0
50-70 | 18 (85.7%) | 3 (14.3%)
>70 | 25 (100.0%) | 0
Current Dose (mg/kg/day)^3^
N | N/A | 3
Mean (SD) | N/A | 36 (29)
Median (Min, Max) | N/A | 50 (3 - 56)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 40 (95.2%) | 2 (4.8%)
>1.2 | 5 (83.3%) | 1 (16.7%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 11 (100.0%) | 0
Cerebrospinal Fluid | 14 (100.0%) | 0
SEM | 12 (85.7%) | 2 (14.3%)
Unknown | 9 (90.0%) | 1 (10.0%)

Note: Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative IV dose while on study acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily IV dose while on study acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.1.4 Listing of Participants with CNS, Hepatic or Renal AEs Participant ID: ▬

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬ | . | Grade 4 IVH | Yes | .
▬ | 20 | Severe Liver Dysfunction | | 0.36
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | | | 0.43
▬ | 60 | | | .
▬ | 60 | | | 0.53
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | Severe Liver Dysfunction | | 0.74
▬ | 60 | | | 0.65
▬ | 60 | | | .
▬ | 60 | | | 0.57
▬ | 60 | | | 0.71
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | Mild Liver Dysfunction | | 0.47
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 80 | Mild Liver Dysfunction | | 0.19
▬ | 60 | | | .
▬ | 60 | Mild Liver Dysfunction | | 0.31
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | Severe Liver Dysfunction | | 0.28
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | Severe Liver Dysfunction | | 0.29
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | Severe Liver Dysfunction | | 0.26
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 60 | Mild Liver Dysfunction | | 0.28
▬ | 60 | | | .
▬ | 60 | | | .
▬ | 40 | | | .
▬ | . | | | 0.27

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬ | 19 | Seizure, Severe Liver Dysfunction | Yes | 1.28
▬ | 58 | Severe Liver Dysfunction | | 1.29
▬ | 58 | Severe Liver Dysfunction | | 1.28
▬ | 38 | Severe Liver Dysfunction | | 1.12
▬ | 60 | Severe Liver Dysfunction | | 1.02
▬ | 41 | Severe Liver Dysfunction | | 1.12
▬ | 41 | Severe Liver Dysfunction | | 1.64
▬ | 21 | Mild Renal Dysfunction and Severe Liver Dysfunction | | 1.79

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 20 | Mild Liver Dysfunction | | 0.4
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.4
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 36 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 20 | Severe Liver Dysfunction | | 0.5
▬▬▬▬▬ | 60 | | | 1.1
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 1.3
▬▬▬▬▬ | 40 | | | 1.6

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | 40 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | .
▬▬▬▬▬ | 60 | | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 80 | Mild Liver Dysfunction | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 79 | | | .
▬▬▬▬▬ | 56 | | | .
▬▬▬▬▬ | 56 | | | .
▬▬▬▬▬ | 56 | | | .
▬▬▬▬▬ | 56 | | | 0.3
▬▬▬▬▬ | 74 | | | .
▬▬▬▬▬ | 54 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | Seizure | Yes | 0.7
▬▬▬▬▬ | 40 | Severe Liver Dysfunction | | .
▬▬▬▬▬ | 20 | Severe Liver Dysfunction | | 1.1

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | 0.6
▬▬▬▬▬ | 40 | Severe Liver Dysfunction | | 0.6
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 1.1
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 1.5
▬▬▬▬▬ | 60 | Mild Renal Dysfunction and Severe Liver Dysfunction | | 1.9
▬▬▬▬▬ | 60 | Mild Renal Dysfunction and Severe Liver Dysfunction | | 2.2
▬▬▬▬▬ | 60 | Mild Renal Dysfunction | | 2.3
▬▬▬▬▬ | 60 | Mild Renal Dysfunction | | 2.5
▬▬▬▬▬ | 60 | Mild Renal Dysfunction | | 2.5
▬▬▬▬▬ | 60 | Mild Renal Dysfunction | | 2.5
▬▬▬▬▬ | 20 | Mild Renal Dysfunction | | 2.8

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 40 | Severe Liver Dysfunction | | 1.3
▬▬▬▬▬ | 60 | | | 1.3
▬▬▬▬▬ | 60 | Seizure, Severe Liver Dysfunction | Yes | 1.7
▬▬▬▬▬ | 20 | | | 1.5

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | Seizure | Yes | .
▬▬▬▬▬ | 39 | Severe Liver Dysfunction | | 1.17
▬▬▬▬▬ | 39 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 20 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.28
▬▬▬▬▬ | 60 | | | 0.38
▬▬▬▬▬ | 60 | | | 0.28
▬▬▬▬▬ | 60 | | | 0.25
▬▬▬▬▬ | 80 | | | .
▬▬▬▬▬ | 60 | | | 0.24
▬▬▬▬▬ | 60 | | | 0.26
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.39
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.29
▬▬▬▬▬ | 40 | | | .
▬▬▬▬▬ | . | | | 0.26
▬▬▬▬▬ | . | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 39 | Grade 4 IVH, Mild Liver Dysfunction | Yes | .
▬▬▬▬▬ | 58 | Mild Liver Dysfunction | | 0.94
▬▬▬▬▬ | 39 | Mild Liver Dysfunction | | 1.42
▬▬▬▬▬ | 10 | Severe Liver Dysfunction | | 1.63
▬▬▬▬▬ | 10 | Mild Renal Dysfunction | | 1.97

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 20 | Severe Liver Dysfunction | | 1.08
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 0.54
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 0.51
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 0.46
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 0.31
▬▬▬▬▬ | 60 | | | 0.23
▬▬▬▬▬ | 60 | | | 0.21
▬▬▬▬▬ | 60 | | | 0.14
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.21
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.29
▬▬▬▬▬ | 60 | | | 0.22
▬▬▬▬▬ | 60 | | | 0.18
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.24
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.39
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.36
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | . | | | 0.24
▬▬▬▬▬ | . | | | 0.26
▬▬▬▬▬ | . | | | 0.31
▬▬▬▬▬ | . | | | 0.27

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | 40 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Seizure | Yes | .
▬▬▬▬▬ | 60 | Grade 4 IVH | Yes | 0.4
▬▬▬▬▬ | 60 | | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.4
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.4
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 20 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | Grade 2 IVH | Yes | .
▬▬▬▬▬ | . | Grade 3 IVH | Yes | .
▬▬▬▬▬ | 20 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | Seizure | Yes | .
▬▬▬▬▬ | 20 | | | .
▬▬▬▬▬ | 30 | | | .
▬▬▬▬▬ | 30 | | | .
▬▬▬▬▬ | 30 | | | .
▬▬▬▬▬ | 30 | | | 0.6
▬▬▬▬▬ | 30 | | | 0.7
▬▬▬▬▬ | 29 | | | .
▬▬▬▬▬ | 58 | | | 0.4
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 58 | | | 0.4
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 58 | | | 0.8
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 39 | | | .
▬▬▬▬▬ | 59 | | | 0.4
▬▬▬▬▬ | 59 | | | 0.5
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | 0.4
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | 0.4
▬▬▬▬▬ | 59 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | Grade 4 IVH | Yes | 0.9
▬▬▬▬▬ | 40 | | | .
▬▬▬▬▬ | 60 | | | 1.4
▬▬▬▬▬ | 40 | Grade 4 IVH, Mild Renal Dysfunction and Severe Liver Dysfunction | Yes | 1.9

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | Seizure | Yes | .
▬▬▬▬▬ | . | | | 0.2
▬▬▬▬▬ | 20 | Seizure | Yes | 0.3
▬▬▬▬▬ | 60 | Grade 4 IVH | Yes | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.3
▬▬▬▬▬ | 60 | | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.3
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 40 | | | 0.3

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 20 | | | 0.3
▬▬▬▬▬ | 61 | Severe Liver Dysfunction | | 0.86
▬▬▬▬▬ | 56 | Renal Failure, Severe Liver Dysfunction | Yes | 1.07
▬▬▬▬▬ | 36 | Severe Liver Dysfunction | | 1.36
▬▬▬▬▬ | 20 | Severe Liver Dysfunction | | 1.5
▬▬▬▬▬ | 20 | Mild Renal Dysfunction and Severe Liver Dysfunction | | 1.76
▬▬▬▬▬ | . | | | 2.22

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 42 | | | .
▬▬▬▬▬ | 127 | | | 0.6
▬▬▬▬▬ | 127 | | | .
▬▬▬▬▬ | 127 | | | 0.6
▬▬▬▬▬ | 127 | | | 0.5
▬▬▬▬▬ | 85 | Seizure | Yes | .
▬▬▬▬▬ | 75 | | | .
▬▬▬▬▬ | 112 | | | 0.4
▬▬▬▬▬ | 112 | | | .
▬▬▬▬▬ | 112 | | | 0.5
▬▬▬▬▬ | 112 | | | .
▬▬▬▬▬ | 112 | | | .
▬▬▬▬▬ | 112 | | | 0.6
▬▬▬▬▬ | 112 | | | .
▬▬▬▬▬ | 112 | | | 0.5
▬▬▬▬▬ | 112 | | | .
▬▬▬▬▬ | 112 | | | .
▬▬▬▬▬ | 112 | | | .
▬▬▬▬▬ | 112 | | | .
▬▬▬▬▬ | 112 | | | 0.4
▬▬▬▬▬ | 112 | Seizure | Yes | .
▬▬▬▬▬ | 37 | | | 0.4
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.2
▬▬▬▬▬ | . | | | 0.2
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.2
▬▬▬▬▬ | . | Seizure | Yes | 0.2
▬▬▬▬▬ | . | | | 0.2
▬▬▬▬▬ | . | | | 0.2
▬▬▬▬▬ | . | Seizure | Yes | 0.2

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | 0.2
▬▬▬▬▬ | 56 | Mild Liver Dysfunction | | 0.3
▬▬▬▬▬ | 88 | | | 0.3
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 63 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 41 | | | 0.5
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 103 | Mild Liver Dysfunction | | 0.3
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 103 | | | 0.3
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 103 | | | .
▬▬▬▬▬ | 34 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 39 | Severe Liver Dysfunction | | 0.7
▬▬▬▬▬ | 58 | Severe Liver Dysfunction | | 0.6
▬▬▬▬▬ | 58 | Severe Liver Dysfunction | | 0.7
▬▬▬▬▬ | . | | | 1
▬▬▬▬▬ | 64 | Severe Liver Dysfunction | | 1
▬▬▬▬▬ | 96 | Seizure, Severe Liver Dysfunction | Yes | 1.1
▬▬▬▬▬ | 96 | Mild Liver Dysfunction | | 1.2
▬▬▬▬▬ | 32 | | | .
▬▬▬▬▬ | 17 | Mild Liver Dysfunction | | 1.2
▬▬▬▬▬ | 33 | Mild Renal and Liver Dysfunction | | 1
▬▬▬▬▬ | 50 | | | 0.8
▬▬▬▬▬ | 50 | | | 0.7
▬▬▬▬▬ | 50 | | | 0.9
▬▬▬▬▬ | 67 | | | .
▬▬▬▬▬ | 51 | | | 0.7
▬▬▬▬▬ | 51 | | | 0.6
▬▬▬▬▬ | 51 | | | .
▬▬▬▬▬ | 51 | | | 0.4
▬▬▬▬▬ | 51 | | | 0.4
▬▬▬▬▬ | 51 | | | 0.4
▬▬▬▬▬ | 51 | | | 0.5
▬▬▬▬▬ | 51 | Seizure | Yes | 0.3
▬▬▬▬▬ | 25 | | | 0.3
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | . | | | 0.5
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | . | | | 0.5
▬▬▬▬▬ | . | | | 0.5
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | . | | | 0.4

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 37 | | | .
▬▬▬▬▬ | 56 | | | 0.4
▬▬▬▬▬ | 56 | | | 0.4
▬▬▬▬▬ | 96 | Mild Liver Dysfunction | | 0.4
▬▬▬▬▬ | 89 | | | 0.4
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | 0.3
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | 0.2
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 89 | | | .
▬▬▬▬▬ | 30 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 38 | | | .
▬▬▬▬▬ | 57 | | | .
▬▬▬▬▬ | 57 | | | .
▬▬▬▬▬ | 57 | | | .
▬▬▬▬▬ | 57 | | | .
▬▬▬▬▬ | 57 | | | .
▬▬▬▬▬ | 68 | Mild Liver Dysfunction | | 0.1
▬▬▬▬▬ | 90 | Mild Liver Dysfunction | | 0.2
▬▬▬▬▬ | 90 | Mild Liver Dysfunction | | 0.1
▬▬▬▬▬ | 90 | | | .
▬▬▬▬▬ | 90 | Mild Liver Dysfunction | | 0.2
▬▬▬▬▬ | 90 | Mild Liver Dysfunction | | 0.2
▬▬▬▬▬ | 90 | Mild Liver Dysfunction | | 0.2
▬▬▬▬▬ | 60 | | | 0.1

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 40 | | | .
▬▬▬▬▬ | 88 | | | 0.4
▬▬▬▬▬ | 102 | | | 0.5
▬▬▬▬▬ | 102 | | | 0.4
▬▬▬▬▬ | 102 | | | .
▬▬▬▬▬ | 102 | Mild Liver Dysfunction | | 0.4
▬▬▬▬▬ | 102 | | | .
▬▬▬▬▬ | 102 | | | 0.3
▬▬▬▬▬ | 102 | | | .
▬▬▬▬▬ | 102 | | | 0.4
▬▬▬▬▬ | 68 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 40 | | | .
▬▬▬▬▬ | 60 | | | 1.6
▬▬▬▬▬ | 43 | | | 1.6
▬▬▬▬▬ | 77 | | | 1.5
▬▬▬▬▬ | 110 | | | 1.5
▬▬▬▬▬ | 110 | | | .
▬▬▬▬▬ | 221 | | | 1.1
▬▬▬▬▬ | 166 | | | .
▬▬▬▬▬ | 166 | | | .
▬▬▬▬▬ | 166 | | | 1.1
▬▬▬▬▬ | 166 | | | .
▬▬▬▬▬ | 166 | | | 1.4
▬▬▬▬▬ | 166 | | | 1.4
▬▬▬▬▬ | 213 | | | 1.5
▬▬▬▬▬ | 95 | | | .
▬▬▬▬▬ | 96 | Mild Renal Dysfunction | | 2.6
▬▬▬▬▬ | 49 | Severe Ranal Dysfunction | | 3.6
▬▬▬▬▬ | 43 | Severe Ranal Dysfunction | | 3.5
▬▬▬▬▬ | 18 | Severe Ranal Dysfunction | | 3.1
▬▬▬▬▬ | 18 | Mild Renal Dysfunction | | 2.5
▬▬▬▬▬ | 18 | Mild Renal Dysfunction | | 2.3
▬▬▬▬▬ | 18 | Severe Ranal Dysfunction | | 3.1
▬▬▬▬▬ | 18 | Mild Renal Dysfunction | | 3
▬▬▬▬▬ | 18 | | | .
▬▬▬▬▬ | 18 | | | .
▬▬▬▬▬ | 18 | Mild Renal Dysfunction | | 2
▬▬▬▬▬ | 18 | Mild Renal Dysfunction | | 1.9
▬▬▬▬▬ | 18 | | | 1.7
▬▬▬▬▬ | 38 | | | 1.2
▬▬▬▬▬ | 40 | | | 1.2
▬▬▬▬▬ | 40 | Mild Renal Dysfunction | | 1.8
▬▬▬▬▬ | 20 | | | 1.1
▬▬▬▬▬ | . | | | 1
▬▬▬▬▬ | . | | | 0.8
▬▬▬▬▬ | . | | | 0.9
▬▬▬▬▬ | . | | | 1.2
▬▬▬▬▬ | . | | | 0.9

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | 1
▬▬▬▬▬ | . | | | 1
▬▬▬▬▬ | . | | | 0.9
▬▬▬▬▬ | . | | | 0.9
▬▬▬▬▬ | . | | | 1.1
▬▬▬▬▬ | . | | | 1.5
▬▬▬▬▬ | . | | | 2.1
▬▬▬▬▬ | 56 | | | .
▬▬▬▬▬ | 169 | Mild Renal Dysfunction | | 1.9
▬▬▬▬▬ | 169 | | | 1.2
▬▬▬▬▬ | 169 | | | 0.7
▬▬▬▬▬ | 140 | | | 0.6
▬▬▬▬▬ | 82 | | | 0.6
▬▬▬▬▬ | 89 | | | 0.6
▬▬▬▬▬ | 62 | | | 0.7
▬▬▬▬▬ | 62 | | | 0.6
▬▬▬▬▬ | 62 | | | 0.6
▬▬▬▬▬ | 62 | | | 0.5
▬▬▬▬▬ | 62 | | | 0.5
▬▬▬▬▬ | 62 | | | .
▬▬▬▬▬ | 62 | | | 0.5
▬▬▬▬▬ | 62 | | | .
▬▬▬▬▬ | 62 | | | 0.4
▬▬▬▬▬ | 62 | | | 0.5
▬▬▬▬▬ | 62 | | | 0.5
▬▬▬▬▬ | 62 | | | 0.4
▬▬▬▬▬ | 62 | | | .
▬▬▬▬▬ | 62 | | | 0.4
▬▬▬▬▬ | 71 | | | 0.4
▬▬▬▬▬ | 36 | | | 0.4
▬▬▬▬▬ | 29 | | | .
▬▬▬▬▬ | 29 | | | .
▬▬▬▬▬ | 29 | | | 0.3
▬▬▬▬▬ | 10 | | | .
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.3

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 38 | | | .
▬▬▬▬▬ | 58 | | | 0.3
▬▬▬▬▬ | 58 | | | 0.2
▬▬▬▬▬ | 58 | Severe Liver Dysfunction | | 0.3
▬▬▬▬▬ | 94 | Severe Liver Dysfunction | | 0.3
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | Mild Liver Dysfunction | | 0.3
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | 0.4
▬▬▬▬▬ | 94 | | | 0.3
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 94 | | | .
▬▬▬▬▬ | 63 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | 0.3
▬▬▬▬▬ | . | | | 0.6
▬▬▬▬▬ | 64 | Severe Liver Dysfunction | | 0.8
▬▬▬▬▬ | 96 | | | 1.1
▬▬▬▬▬ | 96 | | | 1.3
▬▬▬▬▬ | 96 | Mild Liver Dysfunction | | 1.3
▬▬▬▬▬ | 96 | Mild Liver Dysfunction | | 1.3
▬▬▬▬▬ | 96 | Mild Renal Dysfunction | | 1.7
▬▬▬▬▬ | 96 | Mild Renal Dysfunction | | 2.3
▬▬▬▬▬ | 96 | | | .
▬▬▬▬▬ | 96 | Mild Renal Dysfunction | | 2.3
▬▬▬▬▬ | 96 | Mild Renal Dysfunction | | 2.1
▬▬▬▬▬ | 96 | Seizure | Yes | 1.7
▬▬▬▬▬ | 96 | | | .
▬▬▬▬▬ | 96 | | | 1.3
▬▬▬▬▬ | 96 | | | .
▬▬▬▬▬ | 96 | | | 1
▬▬▬▬▬ | 96 | | | .
▬▬▬▬▬ | 96 | | | .
▬▬▬▬▬ | 96 | | | 0.6
▬▬▬▬▬ | 96 | | | 0.6
▬▬▬▬▬ | 96 | | | .
▬▬▬▬▬ | 96 | | | 0.4
▬▬▬▬▬ | 96 | | | .
▬▬▬▬▬ | 195 | | | 0.5
▬▬▬▬▬ | 24 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | 0.4
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | 0.5
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 200 | | | .
▬▬▬▬▬ | 100 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 40 | Mild Liver Dysfunction | | 1.3
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 1.7
▬▬▬▬▬ | 40 | Mild Renal Dysfunction | | 1.8
▬▬▬▬▬ | 50 | Renal Failure, Mild Renal Dysfunction | Yes | 2.3
▬▬▬▬▬ | 20 | | | 1.4
▬▬▬▬▬ | 20 | | | 0.7
▬▬▬▬▬ | 20 | | | 0.4
▬▬▬▬▬ | 20 | | | 0.3
▬▬▬▬▬ | 20 | | | 0.3
▬▬▬▬▬ | 20 | | | 0.4
▬▬▬▬▬ | 20 | Mild Renal Dysfunction | | 0.8
▬▬▬▬▬ | 20 | | | 0.3
▬▬▬▬▬ | 29 | | | 0.3
▬▬▬▬▬ | 27 | | | 0.3
▬▬▬▬▬ | 27 | | | 0.4
▬▬▬▬▬ | 27 | | | 0.3
▬▬▬▬▬ | 37 | | | 0.4
▬▬▬▬▬ | 27 | Mild Liver Dysfunction | | 0.8
▬▬▬▬▬ | 27 | | | 0.5
▬▬▬▬▬ | 27 | | | 0.5
▬▬▬▬▬ | 27 | | | 0.5
▬▬▬▬▬ | 27 | | | 0.4
▬▬▬▬▬ | 27 | | | 0.5
▬▬▬▬▬ | 27 | | | 0.5
▬▬▬▬▬ | 27 | Mild Renal Dysfunction | | 0.7
▬▬▬▬▬ | 27 | Severe Ranal Dysfunction | | 0.7

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | 0.6
▬▬▬▬▬ | 33 | | | .
▬▬▬▬▬ | 50 | | | .
▬▬▬▬▬ | 50 | | | .
▬▬▬▬▬ | 50 | | | .
▬▬▬▬▬ | 50 | | | .
▬▬▬▬▬ | 70 | | | .
▬▬▬▬▬ | 40 | | | .
▬▬▬▬▬ | 40 | | | 0.6
▬▬▬▬▬ | 40 | | | 0.6
▬▬▬▬▬ | 40 | | | 0.6
▬▬▬▬▬ | 55 | | | 0.6
▬▬▬▬▬ | 52 | | | .
▬▬▬▬▬ | 52 | | | .
▬▬▬▬▬ | 52 | | | 0.5
▬▬▬▬▬ | 52 | | | 0.5
▬▬▬▬▬ | 52 | | | 0.6
▬▬▬▬▬ | 77 | | | 0.34
▬▬▬▬▬ | 60 | | | 0.31
▬▬▬▬▬ | 60 | | | 0.38
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.39
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.35
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.39
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.36
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.36
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.34
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.32
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | 0.33
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.32
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.33
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.25
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.32
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.27
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.26
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.24
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 20 | | | 0.28

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | .
▬▬▬▬▬ | 41 | | | 0.32
▬▬▬▬▬ | 62 | | | .
▬▬▬▬▬ | 62 | | | .
▬▬▬▬▬ | 61 | Mild Liver Dysfunction | | 0.45
▬▬▬▬▬ | 60 | | | 0.47
▬▬▬▬▬ | 60 | | | 0.46
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 80 | | | .
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 58 | | | 0.37
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 58 | | | .
▬▬▬▬▬ | 39 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | 0.4
▬▬▬▬▬ | 20 | | | .
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 20 | | | .
▬▬▬▬▬ | . | | | 0.5
▬▬▬▬▬ | 64 | Severe Liver Dysfunction | | 0.36
▬▬▬▬▬ | 64 | | | .
▬▬▬▬▬ | 64 | Severe Liver Dysfunction | | .
▬▬▬▬▬ | 64 | | | .
▬▬▬▬▬ | 64 | Mild Liver Dysfunction | | .
▬▬▬▬▬ | 64 | | | .
▬▬▬▬▬ | 84 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | Mild Liver Dysfunction | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | .
▬▬▬▬▬ | 60 | | | 0.31
▬▬▬▬▬ | 60 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 42 | | | .
▬▬▬▬▬ | 64 | Severe Liver Dysfunction | | 1.23
▬▬▬▬▬ | 65 | | | 1.33
▬▬▬▬▬ | 65 | Severe Liver Dysfunction | | 1.25
▬▬▬▬▬ | 65 | | | 1.13
▬▬▬▬▬ | 65 | | | 1.04
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | 65 | | | .
▬▬▬▬▬ | . | | | 0.71

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | . | | | 0.5
▬▬▬▬▬ | 39 | Mild Liver Dysfunction | | 0.37
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | 0.38
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | 0.3
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | 0.4
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 59 | | | .
▬▬▬▬▬ | 39 | | | .

Date | Dose (mg/kg/day) | Adverse Event | Severe (Yes/No) | Serum Creatinine (mg/dL)
▬▬▬▬▬ | 20 | | | .
▬▬▬▬▬ | 60 | | | 0.2
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 0.7
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 0.6
▬▬▬▬▬ | 60 | Severe Liver Dysfunction | | 1
▬▬▬▬▬ | 20 | Severe Liver Dysfunction | | 1.36
▬▬▬▬▬ | . | | | 1.55
▬▬▬▬▬ | . | | | 1.65
▬▬▬▬▬ | 3 | Renal Failure, Mild Renal and Liver Dysfunction | Yes | 1.92
▬▬▬▬▬ | 9 | Mild Liver Dysfunction | | 0.95
▬▬▬▬▬ | 25 | Severe Liver Dysfunction | | 0.45
▬▬▬▬▬ | 26 | | | 0.33
▬▬▬▬▬ | 26 | | | 0.31
▬▬▬▬▬ | 34 | Severe Liver Dysfunction | | 0.33
▬▬▬▬▬ | 17 | Severe Liver Dysfunction | | 0.38
▬▬▬▬▬ | 38 | | | 0.35
▬▬▬▬▬ | 43 | Mild Liver Dysfunction | | 0.32
▬▬▬▬▬ | 43 | | | 0.2
▬▬▬▬▬ | 43 | Mild Liver Dysfunction | | 0.24
▬▬▬▬▬ | 22 | Mild Liver Dysfunction | | 0.2

Table 14.2.2.1.1 Summary of Laboratory AEs by GA and PNA Group Safety Population

| GA 23-29 weeks; (N=6) | | GA 30-34 weeks; (N=10) | | GA 35-42 weeks; PNA <14 days; (N=25) | | GA 35-42 weeks; PNA >=14 days; (N=8) | | Total; (N=49)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Hyperglycemia
Number of Events | 10 | 2 | 3 | 0 | 23 | 1 | 3 | 0 | 39 | 3
Events per Day^1^ | 0.067 | 0.013 | 0.015 | 0 | 0.045 | 0.002 | 0.020 | 0 | 0.038 | 0.003
Number of Participants | 3 (50.0%) | 1 (16.7%) | 3 (30.0%) | 0 | 10 (40.0%) | 1 (4.0%) | 1 (12.5%) | 0 | 17 (34.7%) | 2 (4.1%)
Hypoglycemia
Number of Events | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 0
Events per Day^1^ | 0 | 0 | 0 | 0 | 0.002 | 0 | 0 | 0 | 0.001 | 0
Number of Participants | 0 | 0 | 0 | 0 | 1 (4.0%) | 0 | 0 | 0 | 1 (2.0%) | 0
Hypernatremia
Number of Events | 0 | 0 | 4 | 2 | 3 | 0 | 0 | 0 | 7 | 2
Events per Day^1^ | 0 | 0 | 0.020 | 0.010 | 0.006 | 0 | 0 | 0 | 0.007 | 0.002
Number of Participants | 0 | 0 | 1 (10.0%) | 1 (10.0%) | 1 (4.0%) | 0 | 0 | 0 | 2 (4.1%) | 1 (2.0%)
Hyponatremia
Number of Events | 4 | 0 | 3 | 0 | 4 | 0 | 1 | 0 | 12 | 0
Events per Day^1^ | 0.027 | 0 | 0.015 | 0 | 0.008 | 0 | 0.007 | 0 | 0.012 | 0
Number of Participants | 1 (16.7%) | 0 | 1 (10.0%) | 0 | 3 (12.0%) | 0 | 1 (12.5%) | 0 | 6 (12.2%) | 0
Hyperkalemia
Number of Events | 0 | 0 | 2 | 0 | 3 | 3 | 1 | 0 | 6 | 3
Events per Day^1^ | 0 | 0 | 0.010 | 0 | 0.006 | 0.006 | 0.007 | 0 | 0.006 | 0.003
Number of Participants | 0 | 0 | 2 (20.0%) | 0 | 2 (8.0%) | 3 (12.0%) | 1 (12.5%) | 0 | 5 (10.2%) | 3 (6.1%)
Hypokalemia
Number of Events | 7 | 0 | 0 | 0 | 6 | 0 | 4 | 0 | 17 | 0
Events per Day^1^ | 0.047 | 0 | 0 | 0 | 0.012 | 0 | 0.026 | 0 | 0.017 | 0
Number of Participants | 3 (50.0%) | 0 | 0 | 0 | 4 (16.0%) | 0 | 2 (25.0%) | 0 | 9 (18.4%) | 0
Elevated BUN
Number of Events | 9 | 0 | 0 | 0 | 6 | 1 | 1 | 0 | 16 | 1
Events per Day^1^ | 0.060 | 0 | 0 | 0 | 0.012 | 0.002 | 0.007 | 0 | 0.016 | 0.001
Number of Participants | 1 (16.7%) | 0 | 0 | 0 | 2 (8.0%) | 1 (4.0%) | 1 (12.5%) | 0 | 4 (8.2%) | 1 (2.0%)
Elevated Creatinine
Number of Events | 9 | 4 | 8 | 0 | 8 | 0 | 0 | 0 | 25 | 4
Events per Day^1^ | 0.060 | 0.027 | 0.039 | 0 | 0.016 | 0 | 0 | 0 | 0.025 | 0.004
Number of Participants | 3 (50.0%) | 1 (16.7%) | 2 (20.0%) | 0 | 5 (20.0%) | 0 | 0 | 0 | 10 (20.4%) | 1 (2.0%)
Elevated ALT
Number of Events | 0 | 0 | 8 | 2 | 32 | 12 | 7 | 4 | 47 | 18
Events per Day^1^ | 0 | 0 | 0.039 | 0.010 | 0.063 | 0.024 | 0.046 | 0.026 | 0.046 | 0.018
Number of Participants | 0 | 0 | 2 (20.0%) | 2 (20.0%) | 14 (56.0%) | 7 (28.0%) | 2 (25.0%) | 1 (12.5%) | 18 (36.7%) | 10 (20.4%)
Elevated AST
Number of Events | 1 | 0 | 3 | 5 | 14 | 32 | 2 | 4 | 20 | 41
Events per Day^1^ | 0.007 | 0 | 0.015 | 0.025 | 0.028 | 0.063 | 0.013 | 0.026 | 0.020 | 0.040
Number of Participants | 1 (16.7%) | 0 | 1 (10.0%) | 2 (20.0%) | 7 (28.0%) | 11 (44.0%) | 2 (25.0%) | 1 (12.5%) | 11 (22.4%) | 14 (28.6%)
Elevated Direct Bilirubin
Number of Events | 4 | 1 | 7 | 0 | 13 | 4 | 8 | 2 | 32 | 7
Events per Day^1^ | 0.027 | 0.007 | 0.034 | 0 | 0.026 | 0.008 | 0.053 | 0.013 | 0.032 | 0.007
Number of Participants | 1 (16.7%) | 1 (16.7%) | 1 (10.0%) | 0 | 8 (32.0%) | 2 (8.0%) | 2 (25.0%) | 1 (12.5%) | 12 (24.5%) | 4 (8.2%)
Elevated GGT
Number of Events | 0 | 0 | 5 | 7 | 13 | 5 | 3 | 0 | 21 | 12
Events per Day^1^ | 0 | 0 | 0.025 | 0.034 | 0.026 | 0.010 | 0.020 | 0 | 0.021 | 0.012
Number of Participants | 0 | 0 | 2 (20.0%) | 2 (20.0%) | 7 (28.0%) | 3 (12.0%) | 2 (25.0%) | 0 | 11 (22.4%) | 5 (10.2%)
Leukocytosis
Number of Events | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0
Events per Day^1^ | 0.007 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0.001 | 0
Number of Participants | 1 (16.7%) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (2.0%) | 0
Leukopenia
Number of Events | 0 | 0 | 4 | 0 | 16 | 0 | 4 | 0 | 24 | 0
Events per Day^1^ | 0 | 0 | 0.020 | 0 | 0.031 | 0 | 0.026 | 0 | 0.024 | 0
Number of Participants | 0 | 0 | 2 (20.0%) | 0 | 10 (40.0%) | 0 | 2 (25.0%) | 0 | 14 (28.6%) | 0
Neutropenia
Number of Events | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Events per Day^1^ | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Thrombocytosis
Number of Events | 15 | 0 | 3 | 0 | 0 | 0 | 5 | 0 | 23 | 0
Events per Day^1^ | 0.100 | 0 | 0.015 | 0 | 0 | 0 | 0.033 | 0 | 0.023 | 0
Number of Participants | 2 (33.3%) | 0 | 2 (20.0%) | 0 | 0 | 0 | 1 (12.5%) | 0 | 5 (10.2%) | 0
Thrombocytopenia
Number of Events | 10 | 0 | 5 | 0 | 79 | 3 | 12 | 0 | 106 | 3
Events per Day^1^ | 0.067 | 0 | 0.025 | 0 | 0.155 | 0.006 | 0.079 | 0 | 0.105 | 0.003
Number of Participants | 3 (50.0%) | 0 | 3 (30.0%) | 0 | 13 (52.0%) | 3 (12.0%) | 2 (25.0%) | 0 | 21 (42.9%) | 3 (6.1%)

Note: Laboratory AEs are attributed to acyclovir if it is presented on a day that the participant was exposed to IV acyclovir.

Only laboratory AEs that occurred on a day of IV acyclovir dosing are included.

1 Events per day is calculated using the total number of events and day on IV acyclovir dosing across all participants.

Table 14.2.2.1.2 Summary of Laboratory AEs by GA, PNA Group and Severity Safety Population

| GA 23-29 weeks; (N=6) | | GA 30-34 weeks; (N=10) | | GA 35-42 weeks; PNA <14 days; (N=25) | | GA 35-42 weeks; PNA >=14 days; (N=8) | | Total; (N=49)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Serum Electrolytes
Number of Events | 21 | 2 | 12 | 2 | 40 | 4 | 9 | 0 | 82 | 8
Number of Participants | 4 (66.7%) | 1 (16.7%) | 5 (50.0%) | 1 (10.0%) | 14 (56.0%) | 3 (12.0%) | 3 (37.5%) | 0 | 26 (53.1%) | 5 (10.2%)
Renal Dysfunction
Number of Events | 18 | 4 | 8 | 0 | 14 | 1 | 1 | 0 | 41 | 5
Number of Participants | 3 (50.0%) | 1 (16.7%) | 2 (20.0%) | 0 | 5 (20.0%) | 1 (4.0%) | 1 (12.5%) | 0 | 11 (22.4%) | 2 (4.1%)
Liver Dysfunction
Number of Events | 5 | 1 | 23 | 14 | 72 | 53 | 20 | 10 | 120 | 78
Number of Participants | 1 (16.7%) | 1 (16.7%) | 3 (30.0%) | 4 (40.0%) | 18 (72.0%) | 12 (48.0%) | 4 (50.0%) | 1 (12.5%) | 26 (53.1%) | 18 (36.7%)
Complete Blood Count
Number of Events | 26 | 0 | 12 | 0 | 95 | 3 | 21 | 0 | 154 | 3
Number of Participants | 5 (83.3%) | 0 | 5 (50.0%) | 0 | 16 (64.0%) | 3 (12.0%) | 3 (37.5%) | 0 | 29 (59.2%) | 3 (6.1%)

Note: Laboratory AEs are attributed to acyclovir if it is presented on a day that the participant was exposed to IV acyclovir.

Only laboratory AEs that occurred on a day of IV acyclovir dosing are included.

Table 14.2.2.2.1 Summary of Laboratory AEs by Site Safety Population

| ▬; (N=13) | | ▬; (N=9) | | ▬; (N=20) | | ▬; (N=7) | | Total; (N=49)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Hyperglycemia
Number of Events | 8 | 1 | 2 | 0 | 21 | 2 | 8 | 0 | 39 | 3
Events per Day^1^ | 0.041 | 0.005 | 0.014 | 0 | 0.046 | 0.004 | 0.037 | 0 | 0.038 | 0.003
Number of Participants | 4 (30.8%) | 1 (7.7%) | 2 (22.2%) | 0 | 8 (40.0%) | 1 (5.0%) | 3 (42.9%) | 0 | 17 (34.7%) | 2 (4.1%)
Hypoglycemia
Number of Events | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0
Events per Day^1^ | 0.005 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0.001 | 0
Number of Participants | 1 (7.7%) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (2.0%) | 0
Hypernatremia
Number of Events | 4 | 2 | 0 | 0 | 0 | 0 | 3 | 0 | 7 | 2
Events per Day^1^ | 0.021 | 0.010 | 0 | 0 | 0 | 0 | 0.014 | 0 | 0.007 | 0.002
Number of Participants | 1 (7.7%) | 1 (7.7%) | 0 | 0 | 0 | 0 | 1 (14.3%) | 0 | 2 (4.1%) | 1 (2.0%)
Hyponatremia
Number of Events | 8 | 0 | 0 | 0 | 4 | 0 | 0 | 0 | 12 | 0
Events per Day^1^ | 0.041 | 0 | 0 | 0 | 0.009 | 0 | 0 | 0 | 0.012 | 0
Number of Participants | 5 (38.5%) | 0 | 0 | 0 | 1 (5.0%) | 0 | 0 | 0 | 6 (12.2%) | 0
Hyperkalemia
Number of Events | 2 | 3 | 1 | 0 | 3 | 0 | 0 | 0 | 6 | 3
Events per Day^1^ | 0.010 | 0.015 | 0.007 | 0 | 0.007 | 0 | 0 | 0 | 0.006 | 0.003
Number of Participants | 2 (15.4%) | 3 (23.1%) | 1 (11.1%) | 0 | 2 (10.0%) | 0 | 0 | 0 | 5 (10.2%) | 3 (6.1%)
Hypokalemia
Number of Events | 2 | 0 | 2 | 0 | 12 | 0 | 1 | 0 | 17 | 0
Events per Day^1^ | 0.010 | 0 | 0.014 | 0 | 0.026 | 0 | 0.005 | 0 | 0.017 | 0
Number of Participants | 1 (7.7%) | 0 | 1 (11.1%) | 0 | 6 (30.0%) | 0 | 1 (14.3%) | 0 | 9 (18.4%) | 0
Elevated BUN
Number of Events | 0 | 0 | 0 | 0 | 16 | 1 | 0 | 0 | 16 | 1
Events per Day^1^ | 0 | 0 | 0 | 0 | 0.035 | 0.002 | 0 | 0 | 0.016 | 0.001
Number of Participants | 0 | 0 | 0 | 0 | 4 (20.0%) | 1 (5.0%) | 0 | 0 | 4 (8.2%) | 1 (2.0%)
Elevated Creatinine
Number of Events | 9 | 0 | 2 | 0 | 13 | 4 | 1 | 0 | 25 | 4
Events per Day^1^ | 0.046 | 0 | 0.014 | 0 | 0.028 | 0.009 | 0.005 | 0 | 0.025 | 0.004
Number of Participants | 3 (23.1%) | 0 | 2 (22.2%) | 0 | 4 (20.0%) | 1 (5.0%) | 1 (14.3%) | 0 | 10 (20.4%) | 1 (2.0%)
Elevated ALT
Number of Events | 18 | 8 | 8 | 3 | 13 | 6 | 8 | 1 | 47 | 18
Events per Day^1^ | 0.092 | 0.041 | 0.054 | 0.020 | 0.028 | 0.013 | 0.037 | 0.005 | 0.046 | 0.018
Number of Participants | 7 (53.8%) | 5 (38.5%) | 2 (22.2%) | 2 (22.2%) | 7 (35.0%) | 2 (10.0%) | 2 (28.6%) | 1 (14.3%) | 18 (36.7%) | 10 (20.4%)
Elevated AST
Number of Events | 6 | 16 | 0 | 11 | 8 | 7 | 6 | 7 | 20 | 41
Events per Day^1^ | 0.031 | 0.082 | 0 | 0.075 | 0.017 | 0.015 | 0.028 | 0.033 | 0.020 | 0.040
Number of Participants | 3 (23.1%) | 6 (46.2%) | 0 | 3 (33.3%) | 7 (35.0%) | 3 (15.0%) | 1 (14.3%) | 2 (28.6%) | 11 (22.4%) | 14 (28.6%)
Elevated Direct Bilirubin
Number of Events | 13 | 1 | 4 | 0 | 14 | 3 | 1 | 3 | 32 | 7
Events per Day^1^ | 0.067 | 0.005 | 0.027 | 0 | 0.031 | 0.007 | 0.005 | 0.014 | 0.032 | 0.007
Number of Participants | 3 (23.1%) | 1 (7.7%) | 1 (11.1%) | 0 | 7 (35.0%) | 2 (10.0%) | 1 (14.3%) | 1 (14.3%) | 12 (24.5%) | 4 (8.2%)
Elevated GGT
Number of Events | 11 | 7 | 0 | 0 | 0 | 0 | 10 | 5 | 21 | 12
Events per Day^1^ | 0.056 | 0.036 | 0 | 0 | 0 | 0 | 0.047 | 0.023 | 0.021 | 0.012
Number of Participants | 6 (46.2%) | 2 (15.4%) | 0 | 0 | 0 | 0 | 5 (71.4%) | 3 (42.9%) | 11 (22.4%) | 5 (10.2%)
Leukocytosis
Number of Events | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 0
Events per Day^1^ | 0 | 0 | 0 | 0 | 0.002 | 0 | 0 | 0 | 0.001 | 0
Number of Participants | 0 | 0 | 0 | 0 | 1 (5.0%) | 0 | 0 | 0 | 1 (2.0%) | 0
Leukopenia
Number of Events | 4 | 0 | 8 | 0 | 10 | 0 | 2 | 0 | 24 | 0
Events per Day^1^ | 0.021 | 0 | 0.054 | 0 | 0.022 | 0 | 0.009 | 0 | 0.024 | 0
Number of Participants | 3 (23.1%) | 0 | 4 (44.4%) | 0 | 6 (30.0%) | 0 | 1 (14.3%) | 0 | 14 (28.6%) | 0
Neutropenia
Number of Events | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Events per Day^1^ | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Thrombocytosis
Number of Events | 0 | 0 | 7 | 0 | 16 | 0 | 0 | 0 | 23 | 0
Events per Day^1^ | 0 | 0 | 0.048 | 0 | 0.035 | 0 | 0 | 0 | 0.023 | 0
Number of Participants | 0 | 0 | 2 (22.2%) | 0 | 3 (15.0%) | 0 | 0 | 0 | 5 (10.2%) | 0
Thrombocytopenia
Number of Events | 20 | 1 | 13 | 0 | 47 | 1 | 26 | 1 | 106 | 3
Events per Day^1^ | 0.103 | 0.005 | 0.088 | 0 | 0.103 | 0.002 | 0.121 | 0.005 | 0.105 | 0.003
Number of Participants | 8 (61.5%) | 1 (7.7%) | 3 (33.3%) | 0 | 7 (35.0%) | 1 (5.0%) | 3 (42.9%) | 1 (14.3%) | 21 (42.9%) | 3 (6.1%)

Note: Laboratory AEs are attributed to acyclovir if it is presented on a day that the participant was exposed to IV acyclovir.

Only laboratory AEs that occurred on a day of IV acyclovir dosing are included.

1 Events per day is calculated using the total number of events and day on IV acyclovir dosing across all participants.

Table 14.2.2.2.2 Summary of Laboratory AEs by Site and Severity Safety Population

| ▬; (N=13) | | ▬; (N=9) | | ▬; (N=20) | | ▬; (N=7) | | Total; (N=49)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Serum Electrolytes
Number of Events | 25 | 6 | 5 | 0 | 40 | 2 | 12 | 0 | 82 | 8
Number of Participants | 9 (69.2%) | 4 (30.8%) | 3 (33.3%) | 0 | 11 (55.0%) | 1 (5.0%) | 3 (42.9%) | 0 | 26 (53.1%) | 5 (10.2%)
Renal Dysfunction
Number of Events | 9 | 0 | 2 | 0 | 29 | 5 | 1 | 0 | 41 | 5
Number of Participants | 3 (23.1%) | 0 | 2 (22.2%) | 0 | 5 (25.0%) | 2 (10.0%) | 1 (14.3%) | 0 | 11 (22.4%) | 2 (4.1%)
Liver Dysfunction
Number of Events | 48 | 32 | 12 | 14 | 35 | 16 | 25 | 16 | 120 | 78
Number of Participants | 10 (76.9%) | 9 (69.2%) | 2 (22.2%) | 3 (33.3%) | 9 (45.0%) | 3 (15.0%) | 5 (71.4%) | 3 (42.9%) | 26 (53.1%) | 18 (36.7%)
Complete Blood Count
Number of Events | 24 | 1 | 28 | 0 | 74 | 1 | 28 | 1 | 154 | 3
Number of Participants | 8 (61.5%) | 1 (7.7%) | 6 (66.7%) | 0 | 12 (60.0%) | 1 (5.0%) | 3 (42.9%) | 1 (14.3%) | 29 (59.2%) | 3 (6.1%)

Note: Laboratory AEs are attributed to acyclovir if it is presented on a day that the participant was exposed to IV acyclovir.

Only laboratory AEs that occurred on a day of IV acyclovir dosing are included.

Table 14.2.2.3.1 Dose Response Analysis of Laboratory AEs-Hyperglycemia Safety Population

| Participants without Hyperglycemia; (n=32) | Participants with Hyperglycemia; (n=17)
GA and PNA Group
GA 23-29 Weeks | 3 (50.0%) | 3 (50.0%)
GA 30-34 Weeks | 7 (70.0%) | 3 (30.0%)
GA 35-42 weeks&PNA <14 days | 15 (60.0%) | 10 (40.0%)
GA 35-42 weeks&PNA >=14 days | 7 (87.5%) | 1 (12.5%)
PMA Group
PMA <30 Weeks | 3 (60.0%) | 2 (40.0%)
PMA 30-35 Weeks | 3 (42.9%) | 4 (57.1%)
PMA >35 Weeks | 25 (69.4%) | 11 (30.6%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 16 (66.7%) | 8 (33.3%)
Male | 16 (64.0%) | 9 (36.0%)
Cumulative Dose (mg/kg)^1^
N | 32 | 17
Mean (SD) | 1575 (1146) | 341 (489)
Median (Min, Max) | 1318 (20 - 6471) | 140 (20 - 1656)
Maximum Dose (mg/kg/day)^2^
N | 32 | 17
Mean (SD) | 96 (80) | 85 (57)
Median (Min, Max) | 80 (20 - 441) | 61 (20 - 221)
<50 | 1 (20.0%) | 4 (80.0%)
50-70 | 14 (63.6%) | 8 (36.4%)
>70 | 17 (77.3%) | 5 (22.7%)
Current Dose (mg/kg/day)^3^
N | N/A | 17
Mean (SD) | N/A | 71 (47)
Median (Min, Max) | N/A | 60 (20 - 182)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 30 (71.4%) | 12 (28.6%)
>1.2 | 1 (16.7%) | 5 (83.3%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 6 (54.5%) | 5 (45.5%)
Cerebrospinal Fluid | 12 (85.7%) | 2 (14.3%)
SEM | 7 (50.0%) | 7 (50.0%)
Unknown | 7 (70.0%) | 3 (30.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.2 Dose Response Analysis of Laboratory AEs-Hypoglycemia Safety Population

| Participants without Hypoglycemia; (n=48) | Participants with Hypoglycemia; (n=1)
GA and PNA Group
GA 23-29 Weeks | 6 (100.0%) | 0
GA 30-34 Weeks | 10 (100.0%) | 0
GA 35-42 weeks&PNA <14 days | 24 (96.0%) | 1 (4.0%)
GA 35-42 weeks&PNA >=14 days | 8 (100.0%) | 0
PMA Group
PMA <30 Weeks | 5 (100.0%) | 0
PMA 30-35 Weeks | 7 (100.0%) | 0
PMA >35 Weeks | 35 (97.2%) | 1 (2.8%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 23 (95.8%) | 1 (4.2%)
Male | 25 (100.0%) | 0
Cumulative Dose (mg/kg)^1^
N | 48 | 1
Mean (SD) | 1658 (1525) | 336
Median (Min, Max) | 1304 (20 - 7178) | 336
Maximum Dose (mg/kg/day)^2^
N | 48 | 1
Mean (SD) | 98 (73) | 60
Median (Min, Max) | 78 (20 - 441) | 60
<50 | 3 (100.0%) | 0
50-70 | 20 (95.2%) | 1 (4.8%)
>70 | 25 (100.0%) | 0
Current Dose (mg/kg/day)^3^
N | N/A | 1
Mean (SD) | N/A | 21
Median (Min, Max) | N/A | 21
Baseline Serum Creatinine (mg/dL)
<=1.2 | 42 (100.0%) | 0
>1.2 | 5 (83.3%) | 1 (16.7%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 10 (90.9%) | 1 (9.1%)
Cerebrospinal Fluid | 14 (100.0%) | 0
SEM | 14 (100.0%) | 0
Unknown | 10 (100.0%) | 0

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.3 Dose Response Analysis of Laboratory AEs-Hypernatremia Safety Population

| Participants without Hypernatremia; (n=47) | Participants with Hypernatremia; (n=2)
GA and PNA Group
GA 23-29 Weeks | 6 (100.0%) | 0
GA 30-34 Weeks | 9 (90.0%) | 1 (10.0%)
GA 35-42 weeks&PNA <14 days | 24 (96.0%) | 1 (4.0%)
GA 35-42 weeks&PNA >=14 days | 8 (100.0%) | 0
PMA Group
PMA <30 Weeks | 5 (100.0%) | 0
PMA 30-35 Weeks | 7 (100.0%) | 0
PMA >35 Weeks | 34 (94.4%) | 2 (5.6%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 24 (100.0%) | 0
Male | 23 (92.0%) | 2 (8.0%)
Cumulative Dose (mg/kg)^1^
N | 47 | 2
Mean (SD) | 1634 (1540) | 290 (43)
Median (Min, Max) | 1292 (20 - 7178) | 290 (259 - 320)
Maximum Dose (mg/kg/day)^2^
N | 47 | 2
Mean (SD) | 98 (74) | 60 (0)
Median (Min, Max) | 77 (20 - 441) | 60 (60 - 60)
<50 | 3 (100.0%) | 0
50-70 | 20 (90.9%) | 2 (9.1%)
>70 | 24 (100.0%) | 0
Current Dose (mg/kg/day)^3^
N | N/A | 2
Mean (SD) | N/A | 60 (0)
Median (Min, Max) | N/A | 60 (60 - 60)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 40 (95.2%) | 2 (4.8%)
>1.2 | 6 (100.0%) | 0
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 10 (90.9%) | 1 (9.1%)
Cerebrospinal Fluid | 14 (100.0%) | 0
SEM | 14 (100.0%) | 0
Unknown | 9 (90.0%) | 1 (10.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.4 Dose Response Analysis of Laboratory AEs-Hyponatremia Safety Population

| Participants without Hyponatremia; (n=43) | Participants with Hyponatremia; (n=6)
GA and PNA Group
GA 23-29 Weeks | 5 (83.3%) | 1 (16.7%)
GA 30-34 Weeks | 9 (90.0%) | 1 (10.0%)
GA 35-42 weeks&PNA <14 days | 22 (88.0%) | 3 (12.0%)
GA 35-42 weeks&PNA >=14 days | 7 (87.5%) | 1 (12.5%)
PMA Group
PMA <30 Weeks | 4 (80.0%) | 1 (20.0%)
PMA 30-35 Weeks | 6 (85.7%) | 1 (14.3%)
PMA >35 Weeks | 32 (88.9%) | 4 (11.1%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 20 (83.3%) | 4 (16.7%)
Male | 23 (92.0%) | 2 (8.0%)
Cumulative Dose (mg/kg)^1^
N | 43 | 6
Mean (SD) | 1640 (1311) | 188 (161)
Median (Min, Max) | 1319 (20 - 6471) | 160 (40 - 486)
Maximum Dose (mg/kg/day)^2^
N | 43 | 6
Mean (SD) | 99 (75) | 74 (54)
Median (Min, Max) | 80 (20 - 441) | 60 (40 - 182)
<50 | 2 (50.0%) | 2 (50.0%)
50-70 | 18 (85.7%) | 3 (14.3%)
>70 | 23 (95.8%) | 1 (4.2%)
Current Dose (mg/kg/day)^3^
N | N/A | 6
Mean (SD) | N/A | 67 (58)
Median (Min, Max) | N/A | 50 (20 - 182)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 38 (90.5%) | 4 (9.5%)
>1.2 | 4 (66.7%) | 2 (33.3%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 8 (72.7%) | 3 (27.3%)
Cerebrospinal Fluid | 11 (78.6%) | 3 (21.4%)
SEM | 14 (100.0%) | 0
Unknown | 10 (100.0%) | 0

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.5 Dose Response Analysis of Laboratory AEs-Hyperkalemia Safety Population

| Participants without Hyperkalemia; (n=42) | Participants with Hyperkalemia; (n=7)
GA and PNA Group
GA 23-29 Weeks | 6 (100.0%) | 0
GA 30-34 Weeks | 8 (80.0%) | 2 (20.0%)
GA 35-42 weeks&PNA <14 days | 21 (84.0%) | 4 (16.0%)
GA 35-42 weeks&PNA >=14 days | 7 (87.5%) | 1 (12.5%)
PMA Group
PMA <30 Weeks | 5 (100.0%) | 0
PMA 30-35 Weeks | 5 (71.4%) | 2 (28.6%)
PMA >35 Weeks | 31 (86.1%) | 5 (13.9%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 20 (83.3%) | 4 (16.7%)
Male | 22 (88.0%) | 3 (12.0%)
Cumulative Dose (mg/kg)^1^
N | 42 | 7
Mean (SD) | 1662 (1397) | 924 (1954)
Median (Min, Max) | 1321 (20 - 7178) | 40 (19 - 5294)
Maximum Dose (mg/kg/day)^2^
N | 42 | 7
Mean (SD) | 93 (56) | 102 (152)
Median (Min, Max) | 80 (20 - 318) | 40 (19 - 441)
<50 | 3 (42.9%) | 4 (57.1%)
50-70 | 16 (94.1%) | 1 (5.9%)
>70 | 23 (92.0%) | 2 (8.0%)
Current Dose (mg/kg/day)^3^
N | N/A | 7
Mean (SD) | N/A | 93 (154)
Median (Min, Max) | N/A | 40 (19 - 441)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 37 (88.1%) | 5 (11.9%)
>1.2 | 4 (66.7%) | 2 (33.3%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 9 (81.8%) | 2 (18.2%)
Cerebrospinal Fluid | 12 (85.7%) | 2 (14.3%)
SEM | 12 (85.7%) | 2 (14.3%)
Unknown | 9 (90.0%) | 1 (10.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.6 Dose Response Analysis of Laboratory AEs-Hypokalemia Safety Population

| Participants without Hypokalemia; (n=40) | Participants with Hypokalemia; (n=9)
GA and PNA Group
GA 23-29 Weeks | 3 (50.0%) | 3 (50.0%)
GA 30-34 Weeks | 10 (100.0%) | 0
GA 35-42 weeks&PNA <14 days | 21 (84.0%) | 4 (16.0%)
GA 35-42 weeks&PNA >=14 days | 6 (75.0%) | 2 (25.0%)
PMA Group
PMA <30 Weeks | 2 (40.0%) | 3 (60.0%)
PMA 30-35 Weeks | 7 (100.0%) | 0
PMA >35 Weeks | 30 (83.3%) | 6 (16.7%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 20 (83.3%) | 4 (16.7%)
Male | 20 (80.0%) | 5 (20.0%)
Cumulative Dose (mg/kg)^1^
N | 40 | 9
Mean (SD) | 1544 (1371) | 1347 (2210)
Median (Min, Max) | 1304 (20 - 6471) | 460 (201 - 6992)
Maximum Dose (mg/kg/day)^2^
N | 40 | 9
Mean (SD) | 93 (76) | 114 (58)
Median (Min, Max) | 64 (20 - 441) | 96 (60 - 221)
<50 | 3 (100.0%) | 0
50-70 | 18 (85.7%) | 3 (14.3%)
>70 | 19 (76.0%) | 6 (24.0%)
Current Dose (mg/kg/day)^3^
N | N/A | 9
Mean (SD) | N/A | 64 (44)
Median (Min, Max) | N/A | 60 (17 - 151)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 36 (85.7%) | 6 (14.3%)
>1.2 | 3 (50.0%) | 3 (50.0%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 10 (90.9%) | 1 (9.1%)
Cerebrospinal Fluid | 11 (78.6%) | 3 (21.4%)
SEM | 11 (78.6%) | 3 (21.4%)
Unknown | 8 (80.0%) | 2 (20.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.7 Dose Response Analysis of Laboratory AEs-Elevated BUN Safety Population

| Participants without Elevated BUN; (n=45) | Participants with Elevated BUN; (n=4)
GA and PNA Group
GA 23-29 Weeks | 5 (83.3%) | 1 (16.7%)
GA 30-34 Weeks | 10 (100.0%) | 0
GA 35-42 weeks&PNA <14 days | 23 (92.0%) | 2 (8.0%)
GA 35-42 weeks&PNA >=14 days | 7 (87.5%) | 1 (12.5%)
PMA Group
PMA <30 Weeks | 4 (80.0%) | 1 (20.0%)
PMA 30-35 Weeks | 7 (100.0%) | 0
PMA >35 Weeks | 33 (91.7%) | 3 (8.3%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 23 (95.8%) | 1 (4.2%)
Male | 22 (88.0%) | 3 (12.0%)
Cumulative Dose (mg/kg)^1^
N | 45 | 4
Mean (SD) | 1564 (1480) | 971 (766)
Median (Min, Max) | 1292 (20 - 7178) | 641 (493 - 2109)
Maximum Dose (mg/kg/day)^2^
N | 45 | 4
Mean (SD) | 93 (71) | 118 (71)
Median (Min, Max) | 65 (20 - 441) | 96 (60 - 221)
<50 | 3 (100.0%) | 0
50-70 | 20 (95.2%) | 1 (4.8%)
>70 | 22 (88.0%) | 3 (12.0%)
Current Dose (mg/kg/day)^3^
N | N/A | 4
Mean (SD) | N/A | 51 (31)
Median (Min, Max) | N/A | 41 (27 - 96)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 40 (95.2%) | 2 (4.8%)
>1.2 | 4 (66.7%) | 2 (33.3%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 11 (100.0%) | 0
Cerebrospinal Fluid | 14 (100.0%) | 0
SEM | 11 (78.6%) | 3 (21.4%)
Unknown | 9 (90.0%) | 1 (10.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.8 Dose Response Analysis of Laboratory AEs-Elevated Creatinine Safety Population

| Participants without Elevated Creatinine; (n=49) | Participants with Elevated Creatinine; (n=0)
GA and PNA Group
GA 23-29 Weeks | 3 (50.0%) | 3 (50.0%)
GA 30-34 Weeks | 8 (80.0%) | 2 (20.0%)
GA 35-42 weeks&PNA <14 days | 20 (80.0%) | 5 (20.0%)
GA 35-42 weeks&PNA >=14 days | 8 (100.0%) | 0
PMA Group
PMA <30 Weeks | 3 (60.0%) | 2 (40.0%)
PMA 30-35 Weeks | 4 (57.1%) | 3 (42.9%)
PMA >35 Weeks | 31 (86.1%) | 5 (13.9%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 19 (79.2%) | 5 (20.8%)
Male | 20 (80.0%) | 5 (20.0%)
Cumulative Dose (mg/kg)^1^
N | 39 | 10
Mean (SD) | 1733 (1504) | 446 (603)
Median (Min, Max) | 1319 (20 - 7178) | 223 (140 - 2109)
Maximum Dose (mg/kg/day)^2^
N | 39 | 10
Mean (SD) | 96 (75) | 91 (58)
Median (Min, Max) | 80 (20 - 441) | 60 (58 - 221)
<50 | 3 (100.0%) | 0
50-70 | 14 (66.7%) | 7 (33.3%)
>70 | 22 (88.0%) | 3 (12.0%)
Current Dose (mg/kg/day)^3^
N | N/A | 10
Mean (SD) | N/A | 51 (50)
Median (Min, Max) | N/A | 40 (3 - 169)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 35 (83.3%) | 7 (16.7%)
>1.2 | 3 (50.0%) | 3 (50.0%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 10 (90.9%) | 1 (9.1%)
Cerebrospinal Fluid | 13 (92.9%) | 1 (7.1%)
SEM | 9 (64.3%) | 5 (35.7%)
Unknown | 7 (70.0%) | 3 (30.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.9 Dose Response Analysis of Laboratory AEs-Elevated ALT Safety Population

| Participants without Elevated ALT; (n=28) | Participants with Elevated ALT; (n=21)
GA and PNA Group
GA 23-29 Weeks | 6 (100.0%) | 0
GA 30-34 Weeks | 7 (70.0%) | 3 (30.0%)
GA 35-42 weeks&PNA <14 days | 9 (36.0%) | 16 (64.0%)
GA 35-42 weeks&PNA >=14 days | 6 (75.0%) | 2 (25.0%)
PMA Group
PMA <30 Weeks | 5 (100.0%) | 0
PMA 30-35 Weeks | 5 (71.4%) | 2 (28.6%)
PMA >35 Weeks | 17 (47.2%) | 19 (52.8%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 16 (66.7%) | 8 (33.3%)
Male | 12 (48.0%) | 13 (52.0%)
Cumulative Dose (mg/kg)^1^
N | 28 | 21
Mean (SD) | 2008 (1656) | 215 (382)
Median (Min, Max) | 1332 (20 - 7178) | 140 (19 - 1780)
Maximum Dose (mg/kg/day)^2^
N | 28 | 21
Mean (SD) | 112 (89) | 56 (21)
Median (Min, Max) | 80 (20 - 441) | 60 (19 - 102)
<50 | 1 (11.1%) | 8 (88.9%)
50-70 | 11 (52.4%) | 10 (47.6%)
>70 | 16 (84.2%) | 3 (15.8%)
Current Dose (mg/kg/day)^3^
N | N/A | 21
Mean (SD) | N/A | 54 (21)
Median (Min, Max) | N/A | 60 (19 - 102)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 24 (57.1%) | 18 (42.9%)
>1.2 | 3 (50.0%) | 3 (50.0%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 5 (45.5%) | 6 (54.5%)
Cerebrospinal Fluid | 10 (71.4%) | 4 (28.6%)
SEM | 9 (64.3%) | 5 (35.7%)
Unknown | 4 (40.0%) | 6 (60.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.10 Dose Response Analysis of Laboratory AEs-Elevated AST Safety Population

| Participants without Elevated AST; (n=28) | Participants with Elevated AST; (n=21)
GA and PNA Group
GA 23-29 Weeks | 5 (83.3%) | 1 (16.7%)
GA 30-34 Weeks | 7 (70.0%) | 3 (30.0%)
GA 35-42 weeks&PNA <14 days | 10 (40.0%) | 15 (60.0%)
GA 35-42 weeks&PNA >=14 days | 6 (75.0%) | 2 (25.0%)
PMA Group
PMA <30 Weeks | 4 (80.0%) | 1 (20.0%)
PMA 30-35 Weeks | 5 (71.4%) | 2 (28.6%)
PMA >35 Weeks | 18 (50.0%) | 18 (50.0%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 15 (62.5%) | 9 (37.5%)
Male | 13 (52.0%) | 12 (48.0%)
Cumulative Dose (mg/kg)^1^
N | 28 | 21
Mean (SD) | 2005 (1660) | 220 (378)
Median (Min, Max) | 1332 (20 - 7178) | 100 (20 - 1780)
Maximum Dose (mg/kg/day)^2^
N | 28 | 21
Mean (SD) | 112 (90) | 59 (20)
Median (Min, Max) | 80 (20 - 441) | 60 (20 - 102)
<50 | 2 (33.3%) | 4 (66.7%)
50-70 | 10 (41.7%) | 14 (58.3%)
>70 | 16 (84.2%) | 3 (15.8%)
Current Dose (mg/kg/day)^3^
N | N/A | 21
Mean (SD) | N/A | 57 (19)
Median (Min, Max) | N/A | 60 (20 - 102)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 24 (57.1%) | 18 (42.9%)
>1.2 | 3 (50.0%) | 3 (50.0%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 6 (54.5%) | 5 (45.5%)
Cerebrospinal Fluid | 10 (71.4%) | 4 (28.6%)
SEM | 9 (64.3%) | 5 (35.7%)
Unknown | 3 (30.0%) | 7 (70.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.11 Dose Response Analysis of Laboratory AEs-Elevated Direct Bilirubin Safety Population

| Participants without Elevated Direct Bilirubin; (n=37) | Participants with Elevated Direct Bilirubin; (n=12)
GA and PNA Group
GA 23-29 Weeks | 5 (83.3%) | 1 (16.7%)
GA 30-34 Weeks | 9 (90.0%) | 1 (10.0%)
GA 35-42 weeks&PNA <14 days | 17 (68.0%) | 8 (32.0%)
GA 35-42 weeks&PNA >=14 days | 6 (75.0%) | 2 (25.0%)
PMA Group
PMA <30 Weeks | 4 (80.0%) | 1 (20.0%)
PMA 30-35 Weeks | 7 (100.0%) | 0
PMA >35 Weeks | 25 (69.4%) | 11 (30.6%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 19 (79.2%) | 5 (20.8%)
Male | 18 (72.0%) | 7 (28.0%)
Cumulative Dose (mg/kg)^1^
N | 37 | 12
Mean (SD) | 1663 (1587) | 325 (258)
Median (Min, Max) | 1292 (20 - 7178) | 274 (56 - 920)
Maximum Dose (mg/kg/day)^2^
N | 37 | 12
Mean (SD) | 100 (81) | 64 (13)
Median (Min, Max) | 65 (20 - 441) | 60 (56 - 103)
<50 | 3 (100.0%) | 0
50-70 | 16 (59.3%) | 11 (40.7%)
>70 | 18 (94.7%) | 1 (5.3%)
Current Dose (mg/kg/day)^3^
N | N/A | 12
Mean (SD) | N/A | 53 (24)
Median (Min, Max) | N/A | 58 (10 - 103)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 32 (76.2%) | 10 (23.8%)
>1.2 | 4 (66.7%) | 2 (33.3%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 9 (81.8%) | 2 (18.2%)
Cerebrospinal Fluid | 11 (78.6%) | 3 (21.4%)
SEM | 11 (78.6%) | 3 (21.4%)
Unknown | 6 (60.0%) | 4 (40.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.12 Dose Response Analysis of Laboratory AEs-Elevated GGT Safety Population

| Participants without Elevated GGT; (n=37) | Participants with Elevated GGT; (n=12)
GA and PNA Group
GA 23-29 Weeks | 6 (100.0%) | 0
GA 30-34 Weeks | 7 (70.0%) | 3 (30.0%)
GA 35-42 weeks&PNA <14 days | 18 (72.0%) | 7 (28.0%)
GA 35-42 weeks&PNA >=14 days | 6 (75.0%) | 2 (25.0%)
PMA Group
PMA <30 Weeks | 5 (100.0%) | 0
PMA 30-35 Weeks | 6 (85.7%) | 1 (14.3%)
PMA >35 Weeks | 25 (69.4%) | 11 (30.6%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 18 (75.0%) | 6 (25.0%)
Male | 19 (76.0%) | 6 (24.0%)
Cumulative Dose (mg/kg)^1^
N | 37 | 12
Mean (SD) | 1675 (1619) | 429 (686)
Median (Min, Max) | 1271 (20 - 7178) | 243 (20 - 2474)
Maximum Dose (mg/kg/day)^2^
N | 37 | 12
Mean (SD) | 106 (81) | 55 (17)
Median (Min, Max) | 90 (20 - 441) | 60 (20 - 80)
<50 | 2 (33.3%) | 4 (66.7%)
50-70 | 16 (72.7%) | 6 (27.3%)
>70 | 19 (90.5%) | 2 (9.5%)
Current Dose (mg/kg/day)^3^
N | N/A | 12
Mean (SD) | N/A | 52 (14)
Median (Min, Max) | N/A | 60 (20 - 64)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 32 (76.2%) | 10 (23.8%)
>1.2 | 4 (66.7%) | 2 (33.3%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 6 (54.5%) | 5 (45.5%)
Cerebrospinal Fluid | 11 (78.6%) | 3 (21.4%)
SEM | 13 (92.9%) | 1 (7.1%)
Unknown | 7 (70.0%) | 3 (30.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.13 Dose Response Analysis of Laboratory AEs-Leukocytosis Safety Population

| Participants without Leukocytosis; (n=48) | Participants with Leukocytosis; (n=1)
GA and PNA Group
GA 23-29 Weeks | 5 (83.3%) | 1 (16.7%)
GA 30-34 Weeks | 10 (100.0%) | 0
GA 35-42 weeks&PNA <14 days | 25 (100.0%) | 0
GA 35-42 weeks&PNA >=14 days | 8 (100.0%) | 0
PMA Group
PMA <30 Weeks | 4 (80.0%) | 1 (20.0%)
PMA 30-35 Weeks | 7 (100.0%) | 0
PMA >35 Weeks | 36 (100.0%) | 0
Not Reported | 1 (100.0%) | 0
Gender
Female | 24 (100.0%) | 0
Male | 24 (96.0%) | 1 (4.0%)
Cumulative Dose (mg/kg)^1^
N | 48 | 1
Mean (SD) | 1601 (1522) | 51
Median (Min, Max) | 1284 (20 - 7178) | 51
Maximum Dose (mg/kg/day)^2^
N | 48 | 1
Mean (SD) | 96 (73) | 51
Median (Min, Max) | 71 (20 - 441) | 51
<50 | 3 (100.0%) | 0
50-70 | 21 (95.5%) | 1 (4.5%)
>70 | 24 (100.0%) | 0
Current Dose (mg/kg/day)^3^
N | N/A | 1
Mean (SD) | N/A | 51
Median (Min, Max) | N/A | 51
Baseline Serum Creatinine (mg/dL)
<=1.2 | 41 (97.6%) | 1 (2.4%)
>1.2 | 6 (100.0%) | 0
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 11 (100.0%) | 0
Cerebrospinal Fluid | 13 (92.9%) | 1 (7.1%)
SEM | 14 (100.0%) | 0
Unknown | 10 (100.0%) | 0

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.14 Dose Response Analysis of Laboratory AEs-Leukopenia Safety Population

| Participants without Leukopenia; (n=35) | Participants with Leukopenia; (n=14)
GA and PNA Group
GA 23-29 Weeks | 6 (100.0%) | 0
GA 30-34 Weeks | 8 (80.0%) | 2 (20.0%)
GA 35-42 weeks&PNA <14 days | 15 (60.0%) | 10 (40.0%)
GA 35-42 weeks&PNA >=14 days | 6 (75.0%) | 2 (25.0%)
PMA Group
PMA <30 Weeks | 5 (100.0%) | 0
PMA 30-35 Weeks | 5 (71.4%) | 2 (28.6%)
PMA >35 Weeks | 25 (69.4%) | 11 (30.6%)
Not Reported | 0 | 1 (100.0%)
Gender
Female | 17 (70.8%) | 7 (29.2%)
Male | 18 (72.0%) | 7 (28.0%)
Cumulative Dose (mg/kg)^1^
N | 35 | 14
Mean (SD) | 1817 (1578) | 247 (355)
Median (Min, Max) | 1324 (20 - 7178) | 95 (40 - 1160)
Maximum Dose (mg/kg/day)^2^
N | 35 | 14
Mean (SD) | 104 (82) | 62 (15)
Median (Min, Max) | 80 (20 - 441) | 60 (40 - 96)
<50 | 2 (50.0%) | 2 (50.0%)
50-70 | 13 (56.5%) | 10 (43.5%)
>70 | 20 (90.9%) | 2 (9.1%)
Current Dose (mg/kg/day)^3^
N | N/A | 14
Mean (SD) | N/A | 53 (17)
Median (Min, Max) | N/A | 58 (20 - 88)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 30 (71.4%) | 12 (28.6%)
>1.2 | 4 (66.7%) | 2 (33.3%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 9 (81.8%) | 2 (18.2%)
Cerebrospinal Fluid | 11 (78.6%) | 3 (21.4%)
SEM | 9 (64.3%) | 5 (35.7%)
Unknown | 6 (60.0%) | 4 (40.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.15 Dose Response Analysis of Laboratory AEs-Thrombocytosis Safety Population

| Participants without Thrombocytosis; (n=44) | Participants with Thrombocytosis; (n=5)
GA and PNA Group
GA 23-29 Weeks | 4 (66.7%) | 2 (33.3%)
GA 30-34 Weeks | 8 (80.0%) | 2 (20.0%)
GA 35-42 weeks&PNA <14 days | 25 (100.0%) | 0
GA 35-42 weeks&PNA >=14 days | 7 (87.5%) | 1 (12.5%)
PMA Group
PMA <30 Weeks | 3 (60.0%) | 2 (40.0%)
PMA 30-35 Weeks | 5 (71.4%) | 2 (28.6%)
PMA >35 Weeks | 36 (100.0%) | 0
Not Reported | 0 | 1 (100.0%)
Gender
Female | 22 (91.7%) | 2 (8.3%)
Male | 22 (88.0%) | 3 (12.0%)
Cumulative Dose (mg/kg)^1^
N | 44 | 5
Mean (SD) | 1581 (1580) | 881 (673)
Median (Min, Max) | 1284 (20 - 7178) | 928 (80 - 1610)
Maximum Dose (mg/kg/day)^2^
N | 44 | 5
Mean (SD) | 94 (73) | 102 (41)
Median (Min, Max) | 71 (20 - 441) | 110 (60 - 151)
<50 | 3 (100.0%) | 0
50-70 | 19 (90.5%) | 2 (9.5%)
>70 | 22 (88.0%) | 3 (12.0%)
Current Dose (mg/kg/day)^3^
N | N/A | 5
Mean (SD) | N/A | 88 (26)
Median (Min, Max) | N/A | 96 (60 - 112)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 38 (90.5%) | 4 (9.5%)
>1.2 | 5 (83.3%) | 1 (16.7%)
Not Reported | 1 (100.0%) | 0
Baseline Type of Positive HSV
Blood | 11 (100.0%) | 0
Cerebrospinal Fluid | 12 (85.7%) | 2 (14.3%)
SEM | 12 (85.7%) | 2 (14.3%)
Unknown | 9 (90.0%) | 1 (10.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.3.16 Dose Response Analysis of Laboratory AEs-Thrombocytopenia Safety Population

| Participants without Thrombocytopenia; (n=28) | Participants with Thrombocytopenia; (n=21)
GA and PNA Group
GA 23-29 Weeks | 3 (50.0%) | 3 (50.0%)
GA 30-34 Weeks | 7 (70.0%) | 3 (30.0%)
GA 35-42 weeks&PNA <14 days | 12 (48.0%) | 13 (52.0%)
GA 35-42 weeks&PNA >=14 days | 6 (75.0%) | 2 (25.0%)
PMA Group
PMA <30 Weeks | 3 (60.0%) | 2 (40.0%)
PMA 30-35 Weeks | 4 (57.1%) | 3 (42.9%)
PMA >35 Weeks | 20 (55.6%) | 16 (44.4%)
Not Reported | 1 (100.0%) | 0
Gender
Female | 14 (58.3%) | 10 (41.7%)
Male | 14 (56.0%) | 11 (44.0%)
Cumulative Dose (mg/kg)^1^
N | 28 | 21
Mean (SD) | 1850 (1576) | 288 (383)
Median (Min, Max) | 1318 (79 - 7178) | 136 (19 - 1496)
Maximum Dose (mg/kg/day)^2^
N | 28 | 21
Mean (SD) | 110 (88) | 63 (32)
Median (Min, Max) | 80 (40 - 441) | 60 (19 - 169)
<50 | 1 (14.3%) | 6 (85.7%)
50-70 | 12 (52.2%) | 11 (47.8%)
>70 | 15 (78.9%) | 4 (21.1%)
Current Dose (mg/kg/day)^3^
N | N/A | 21
Mean (SD) | N/A | 52 (25)
Median (Min, Max) | N/A | 60 (9 - 96)
Baseline Serum Creatinine (mg/dL)
<=1.2 | 25 (59.5%) | 17 (40.5%)
>1.2 | 3 (50.0%) | 3 (50.0%)
Not Reported | 0 | 1 (100.0%)
Baseline Type of Positive HSV
Blood | 5 (45.5%) | 6 (54.5%)
Cerebrospinal Fluid | 8 (57.1%) | 6 (42.9%)
SEM | 10 (71.4%) | 4 (28.6%)
Unknown | 5 (50.0%) | 5 (50.0%)

Note: If a lab event occurs multiple times at different severity levels while on IV acyclovir, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all IV doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative IV dose from study start to the day of the event. Participants Without Event: the cumulative dose while on IV acyclovir.

2 Maximum Dose-Participants With Event: maximum daily IV dose up to the day of the event. Participants Without Event: maximum daily dose while on IV acyclovir.

3 Current Dose-Participants With Event: the daily IV dose on the day of the event.

Table 14.2.2.4.1.1 Summary of Post-baseline^1^ Serum Liver Biochemistries Worse-Grade Toxicities by GA and PNA Group Safety Population

Serum Liver Biochemistries | Age Strata | | | | Total; (N=49)
Serum Liver Biochemistries | GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
ALT
Grade 0 ^2^ | 0 | 6 (60.0%) | 8 (32.0%) | 5 (62.5%) | 19 (38.8%)
Grade 1 (1.25 to < 2.5 × ULN) | 0 | 0 | 2 (8.0%) | 0 | 2 (4.1%)
Grade 2 (≥ 2.5 - < 5 × ULN) | 1 (16.7%) | 0 | 1 (4.0%) | 0 | 2 (4.1%)
Grade 3 (≥ 5 - < 10 × ULN) | 0 | 0 | 4 (16.0%) | 0 | 4 (8.2%)
Grade 4 (≥ 10 × ULN) | 0 | 2 (20.0%) | 7 (28.0%) | 0 | 9 (18.4%)
Missing post-baseline values | 5 (83.3%) | 2 (20.0%) | 3 (12.0%) | 3 (37.5%) | 13 (26.5%)
AST
Grade 0 ^2^ | 0 | 5 (50.0%) | 4 (16.0%) | 5 (62.5%) | 14 (28.6%)
Grade 1 (1.25 to < 2.5 × ULN) | 0 | 0 | 3 (12.0%) | 0 | 3 (6.1%)
Grade 2 (≥ 2.5 - < 5 × ULN) | 0 | 0 | 3 (12.0%) | 0 | 3 (6.1%)
Grade 3 (≥ 5 - < 10 × ULN) | 1 (16.7%) | 1 (10.0%) | 2 (8.0%) | 0 | 4 (8.2%)
Grade 4 (≥ 10 × ULN) | 0 | 2 (20.0%) | 10 (40.0%) | 0 | 12 (24.5%)
Missing post-baseline values | 5 (83.3%) | 2 (20.0%) | 3 (12.0%) | 3 (37.5%) | 13 (26.5%)
Bilirubin (direct)
Grade 0 ^2^ | 3 (50.0%) | 3 (30.0%) | 9 (36.0%) | 2 (25.0%) | 17 (34.7%)
Grade 1 (1.1 to < 1.6 × ULN) | 0 | 0 | 1 (4.0%) | 1 (12.5%) | 2 (4.1%)
Grade 2 (1.6 to < 2.6 × ULN) | 0 | 0 | 2 (8.0%) | 0 | 2 (4.1%)
Grade 3 (2.6 - 5.0 × ULN) | 0 | 1 (10.0%) | 2 (8.0%) | 0 | 3 (6.1%)
Grade 4 (> 5.0 × ULN) | 1 (16.7%) | 1 (10.0%) | 7 (28.0%) | 1 (12.5%) | 10 (20.4%)
Missing post-baseline values | 2 (33.3%) | 5 (50.0%) | 4 (16.0%) | 4 (50.0%) | 15 (30.6%)

Note:

1 Baseline biochemistry is the closest lab value prior to the first IV acyclovir dosing.

2 Grade 0 includes participants with baseline value worse than the worst post-baseline value and post-baseline values within normal range.

ULN of ALT: 45 U/L, ULN of AST: 120 U/L, ULN of direct bilirubin: 0.7 mg/dL.

Table 14.2.2.4.1.2 Summary of Post-baseline^1^ Serum Liver Biochemistries Worse-Grade Toxicities by Maximum Dose Group Safety Population

Serum Liver Biochemistries | Maximum Daily Dose | | | Total; (N=49)
Serum Liver Biochemistries | <50mg; (N=21) | 50-70mg; (N=3) | >70mg; (N=25) | Total; (N=49)
ALT
Grade 0 ^2^ | 9 (42.9%) | 0 | 10 (40.0%) | 19 (38.8%)
Grade 1 (1.25 to < 2.5 × ULN) | 2 (9.5%) | 0 | 0 | 2 (4.1%)
Grade 2 (≥ 2.5 - < 5 × ULN) | 1 (4.8%) | 0 | 1 (4.0%) | 2 (4.1%)
Grade 3 (≥ 5 - < 10 × ULN) | 1 (4.8%) | 0 | 3 (12.0%) | 4 (8.2%)
Grade 4 (≥ 10 × ULN) | 5 (23.8%) | 1 (33.3%) | 3 (12.0%) | 9 (18.4%)
Missing post-baseline values | 3 (14.3%) | 2 (66.7%) | 8 (32.0%) | 13 (26.5%)
AST
Grade 0 ^2^ | 5 (23.8%) | 0 | 9 (36.0%) | 14 (28.6%)
Grade 1 (1.25 to < 2.5 × ULN) | 1 (4.8%) | 0 | 2 (8.0%) | 3 (6.1%)
Grade 2 (≥ 2.5 - < 5 × ULN) | 2 (9.5%) | 0 | 1 (4.0%) | 3 (6.1%)
Grade 3 (≥ 5 - < 10 × ULN) | 2 (9.5%) | 0 | 2 (8.0%) | 4 (8.2%)
Grade 4 (≥ 10 × ULN) | 8 (38.1%) | 1 (33.3%) | 3 (12.0%) | 12 (24.5%)
Missing post-baseline values | 3 (14.3%) | 2 (66.7%) | 8 (32.0%) | 13 (26.5%)
Bilirubin (direct)
Grade 0 ^2^ | 6 (28.6%) | 1 (33.3%) | 10 (40.0%) | 17 (34.7%)
Grade 1 (1.1 to < 1.6 × ULN) | 0 | 0 | 2 (8.0%) | 2 (4.1%)
Grade 2 (1.6 to < 2.6 × ULN) | 1 (4.8%) | 0 | 1 (4.0%) | 2 (4.1%)
Grade 3 (2.6 - 5.0 × ULN) | 3 (14.3%) | 0 | 0 | 3 (6.1%)
Grade 4 (> 5.0 × ULN) | 5 (23.8%) | 0 | 5 (20.0%) | 10 (20.4%)
Missing post-baseline values | 6 (28.6%) | 2 (66.7%) | 7 (28.0%) | 15 (30.6%)

Note:

1 Baseline biochemistry is the closest lab value prior to the first IV acyclovir dosing.

2 Grade 0 includes participants with baseline value worse than the worst post-baseline value and post-baseline values within normal range.

ULN of ALT: 45 U/L, ULN of AST: 120 U/L, ULN of direct bilirubin: 0.7 mg/dL.

Table 14.2.2.4.2.1 Summary of Post-baseline^1^ Serum Creatinine Worse-Grade Toxicities by GA and PNA Group Safety Population

Increased Serum Creatinine | Age Strata | | | | Total; (N=49)
Increased Serum Creatinine | GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
Grade 0 ^2^ | 2 (33.3%) | 2 (20.0%) | 9 (36.0%) | 7 (87.5%) | 20 (40.8%)
Grade 1 (1.1 to 1.3 × ULN) | 0 | 1 (10.0%) | 5 (20.0%) | 0 | 6 (12.2%)
Grade 2 (> 1.3 to 1.8 × ULN OR Increase of > 0.3 mg/dL above baseline | 1 (16.7%) | 4 (40.0%) | 7 (28.0%) | 1 (12.5%) | 13 (26.5%)
Grade 3 > (1.8 to < 3.5 × ULN OR Increase of 1.5 to < 2.0 × above baseline) | 0 | 3 (30.0%) | 1 (4.0%) | 0 | 4 (8.2%)
Grade 4 (≥ 3.5 × ULN OR Increase of ≥ 2.0 × ab | 2 (33.3%) | 0 | 1 (4.0%) | 0 | 3 (6.1%)
Missing post-baseline values | 1 (16.7%) | 0 | 2 (8.0%) | 0 | 3 (6.1%)

Note:

1 Baseline biochemistry is the closest lab value prior to the first IV acyclovir dosing.

2 Grade 0 includes participants with baseline creatinine value worse than the worst post-baseline value and post-baseline values within normal range.

ULN of creatinine: 0.4 mg/dL.

Table 14.2.2.4.2.2 Summary of Post-baseline^1^ Serum Creatinine Worse-Grade Toxicities by Maximum Dose Group Safety Population

Increased Serum Creatinine | Maximum Daily Dose | | | Total; (N=49)
Increased Serum Creatinine | <50mg; (N=21) | 50-70mg; (N=3) | >70mg; (N=25) | Total; (N=49)
Grade 0 ^2^ | 7 (33.3%) | 0 | 13 (52.0%) | 20 (40.8%)
Grade 1 (1.1 to 1.3 × ULN) | 2 (9.5%) | 0 | 4 (16.0%) | 6 (12.2%)
Grade 2 (> 1.3 to 1.8 × ULN OR Increase of > 0.3 mg/dL above baseline | 7 (33.3%) | 1 (33.3%) | 5 (20.0%) | 13 (26.5%)
Grade 3 > (1.8 to < 3.5 × ULN OR Increase of 1.5 to < 2.0 × above baseline) | 2 (9.5%) | 0 | 2 (8.0%) | 4 (8.2%)
Grade 4 (≥ 3.5 × ULN OR Increase of ≥ 2.0 × ab | 2 (9.5%) | 0 | 1 (4.0%) | 3 (6.1%)
Missing post-baseline values | 1 (4.8%) | 2 (66.7%) | 0 | 3 (6.1%)

Note:

1 Baseline biochemistry is the closest lab value prior to the first IV acyclovir dosing.

2 Grade 0 includes participants with baseline creatinine value worse than the worst post-baseline value and post-baseline values within normal range.

ULN of creatinine: 0.4 mg/dL.

Table 14.2.2.4.3.1 Summary of Post-baseline^1^ Hematology Biochemistries Worse-Grade Toxicities by GA and PNA Group Safety Population

Hematology Biochemistries | Age Strata | | | | Total; (N=49)
Hematology Biochemistries | GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
WBC, Elevated
Grade 0 ^2^ | 5 (83.3%) | 10 (100.0%) | 24 (96.0%) | 8 (100.0%) | 47 (95.9%)
Grade 1 (≥30*10^9^/L) | 1 (16.7%) | 0 | 0 | 0 | 1 (2.0%)
Grade 2 (≥50*10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 3 (≥75*10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 4 (≥100*10^9^/L) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 0 | 1 (4.0%) | 0 | 1 (2.0%)
WBC, Decreased
Grade 0 ^2^ | 6 (100.0%) | 10 (100.0%) | 24 (96.0%) | 8 (100.0%) | 48 (98.0%)
Grade 1 (≤2*10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 2 (≤1.5*10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 3 (≤1*10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 4 (≤0.5*10^9^/L) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 0 | 1 (4.0%) | 0 | 1 (2.0%)
Hematocrit, Elevated
Grade 0 ^2^ | 6 (100.0%) | 10 (100.0%) | 24 (96.0%) | 8 (100.0%) | 48 (98.0%)
Grade 1 (≥60%) | 0 | 0 | 0 | 0 | 0
Grade 2 (≥65%) | 0 | 0 | 0 | 0 | 0
Grade 3 (≥70%) | 0 | 0 | 0 | 0 | 0
Grade 4 (≥75%) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 0 | 1 (4.0%) | 0 | 1 (2.0%)
Hematocrit, Decreased
Grade 0 ^2^ | 2 (33.3%) | 2 (20.0%) | 9 (36.0%) | 1 (12.5%) | 14 (28.6%)
Grade 1^*^ | 0 | 0 | 1 (4.0%) | 0 | 1 (2.0%)
Grade 2^*^ | 0 | 4 (40.0%) | 5 (20.0%) | 0 | 9 (18.4%)
Grade 3^*^ | 1 (16.7%) | 3 (30.0%) | 5 (20.0%) | 5 (62.5%) | 14 (28.6%)
Grade 4^*^ | 3 (50.0%) | 1 (10.0%) | 4 (16.0%) | 2 (25.0%) | 10 (20.4%)
Missing post-baseline values | 0 | 0 | 1 (4.0%) | 0 | 1 (2.0%)
Platelets, Elevated
Grade 0 ^2^ | 1 (16.7%) | 4 (40.0%) | 12 (48.0%) | 5 (62.5%) | 22 (44.9%)
Grade 1 (≥400*10^9^/L) | 0 | 3 (30.0%) | 7 (28.0%) | 2 (25.0%) | 12 (24.5%)
Grade 2 (≥500*10^9^/L) | 4 (66.7%) | 3 (30.0%) | 5 (20.0%) | 1 (12.5%) | 13 (26.5%)
Grade 3 (≥750*10^9^/L) | 1 (16.7%) | 0 | 0 | 0 | 1 (2.0%)
Grade 4 (≥1000*10^9^/L) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 0 | 1 (4.0%) | 0 | 1 (2.0%)
Platelets, Decreased
Grade 0 ^2^ | 4 (66.7%) | 8 (80.0%) | 11 (44.0%) | 6 (75.0%) | 29 (59.2%)
Grade 1 (<125*10^9^/L) | 1 (16.7%) | 0 | 1 (4.0%) | 1 (12.5%) | 3 (6.1%)
Grade 2 (<100*10^9^/L) | 0 | 1 (10.0%) | 5 (20.0%) | 0 | 6 (12.2%)
Grade 3 (<50*10^9^/L) | 1 (16.7%) | 1 (10.0%) | 4 (16.0%) | 1 (12.5%) | 7 (14.3%)
Grade 4 (<25*10^9^/L) | 0 | 0 | 3 (12.0%) | 0 | 3 (6.1%)
Missing post-baseline values | 0 | 0 | 1 (4.0%) | 0 | 1 (2.0%)

Note:

1 Baseline biochemistry is the closest lab value prior to the first IV acyclovir dosing.

2 Grade 0 includes participants with baseline value worse than the worst post-baseline value and post-baseline values within normal range.

* HCT Grades are from DAIDS levels based on PNA under convention 3x HGB.

Table 14.2.2.4.3.2 Summary of Post-baseline^1^ Hematology Biochemistries Worse-Grade Toxicities by Maximum Dose Group Safety Population

Hematology Biochemistries | Maximum Daily Dose | | | Total; (N=49)
Hematology Biochemistries | <50mg; (N=21) | 50-70mg; (N=3) | >70mg; (N=25) | Total; (N=49)
WBC, Elevated
Grade 0 ^2^ | 20 (95.2%) | 2 (66.7%) | 25 (100.0%) | 47 (95.9%)
Grade 1 (≥30*10^9^/L) | 1 (4.8%) | 0 | 0 | 1 (2.0%)
Grade 2 (≥50*10^9^/L) | 0 | 0 | 0 | 0
Grade 3 (≥75*10^9^/L) | 0 | 0 | 0 | 0
Grade 4 (≥100*10^9^/L) | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 1 (33.3%) | 0 | 1 (2.0%)
WBC, Decreased
Grade 0 ^2^ | 21 (100.0%) | 2 (66.7%) | 25 (100.0%) | 48 (98.0%)
Grade 1 (≤2*10^9^/L) | 0 | 0 | 0 | 0
Grade 2 (≤1.5*10^9^/L) | 0 | 0 | 0 | 0
Grade 3 (≤1*10^9^/L) | 0 | 0 | 0 | 0
Grade 4 (≤0.5*10^9^/L) | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 1 (33.3%) | 0 | 1 (2.0%)
Hematocrit, Elevated
Grade 0 ^2^ | 21 (100.0%) | 2 (66.7%) | 25 (100.0%) | 48 (98.0%)
Grade 1 (≥60%) | 0 | 0 | 0 | 0
Grade 2 (≥65%) | 0 | 0 | 0 | 0
Grade 3 (≥70%) | 0 | 0 | 0 | 0
Grade 4 (≥75%) | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 1 (33.3%) | 0 | 1 (2.0%)
Hematocrit, Decreased
Grade 0 ^2^ | 7 (33.3%) | 1 (33.3%) | 6 (24.0%) | 14 (28.6%)
Grade 1^*^ | 1 (4.8%) | 0 | 0 | 1 (2.0%)
Grade 2^*^ | 3 (14.3%) | 0 | 6 (24.0%) | 9 (18.4%)
Grade 3^*^ | 7 (33.3%) | 0 | 7 (28.0%) | 14 (28.6%)
Grade 4^*^ | 3 (14.3%) | 1 (33.3%) | 6 (24.0%) | 10 (20.4%)
Missing post-baseline values | 0 | 1 (33.3%) | 0 | 1 (2.0%)
Platelets, Elevated
Grade 0 ^2^ | 11 (52.4%) | 1 (33.3%) | 10 (40.0%) | 22 (44.9%)
Grade 1 (≥400*10^9^/L) | 7 (33.3%) | 0 | 5 (20.0%) | 12 (24.5%)
Grade 2 (≥500*10^9^/L) | 3 (14.3%) | 0 | 10 (40.0%) | 13 (26.5%)
Grade 3 (≥750*10^9^/L) | 0 | 1 (33.3%) | 0 | 1 (2.0%)
Grade 4 (≥1000*10^9^/L) | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 1 (33.3%) | 0 | 1 (2.0%)
Platelets, Decreased
Grade 0 ^2^ | 14 (66.7%) | 1 (33.3%) | 14 (56.0%) | 29 (59.2%)
Grade 1 (<125*10^9^/L) | 1 (4.8%) | 0 | 2 (8.0%) | 3 (6.1%)
Grade 2 (<100*10^9^/L) | 1 (4.8%) | 1 (33.3%) | 4 (16.0%) | 6 (12.2%)
Grade 3 (<50*10^9^/L) | 3 (14.3%) | 0 | 4 (16.0%) | 7 (14.3%)
Grade 4 (<25*10^9^/L) | 2 (9.5%) | 0 | 1 (4.0%) | 3 (6.1%)
Missing post-baseline values | 0 | 1 (33.3%) | 0 | 1 (2.0%)

Note:

1 Baseline biochemistry is the closest lab value prior to the first IV acyclovir dosing.

2 Grade 0 includes participants with baseline value worse than the worst post-baseline value and post-baseline values within normal range.

* HCT Grades are from DAIDS levels based on PNA under convention 3x HGB.

Table 14.2.3.1.1 Summary of Positive HSV Diagnostic Tests at Baseline by GA and PNA Group Safety Population

| Age Strata | | | | Total; (N=49)
| GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
Number of Participants with Positive HSV Diagnostic Tests at Baseline | 5 (83.3%) | 9 (90.0%) | 18 (72.0%) | 7 (87.5%) | 39 (79.6%)
Participants with Positive HSV Diagnostic Tests by Type
HSV Viral Culture | 3 | 3 | 2 | 1 | 9
HSV DNA PCR | 3 | 7 | 16 | 6 | 32
HSV direct immunofluorescence assay | 0 | 1 | 0 | 0 | 1
Participants with Positive HSV Diagnostic Tests by Specimen Type
Blood | 1 | 4 | 5 | 1 | 11
Cerebrospinal fluid | 2 | 4 | 7 | 4 | 17
Conjunctivae | 1 | 0 | 1 | 0 | 2
Mouth | 1 | 0 | 1 | 1 | 3
Naso/oropharynx | 1 | 1 | 3 | 1 | 6
Rectum | 1 | 1 | 3 | 1 | 6
Skin or mucous membrane lesions | 4 | 5 | 4 | 3 | 16
Participants with Positive HSV Diagnostic Tests by Finding Type
Herpes simplex virus (unspecified) | 3 | 3 | 1 | 0 | 7
Herpes simplex virus - 1 | 1 | 0 | 9 | 3 | 13
Herpes simplex virus - 2 | 2 | 7 | 8 | 4 | 21

Note: This table includes all positive HSV diagnostic tests collected on or before the date of first reported IV acyclovir dose.

Multiple types and findings of HSV diagnostic tests per participant may be reported at baseline.

Table 14.2.3.1.2 Summary of Positive HSV Diagnostic Tests at End of Study by GA and PNA Group Safety Population

| Age Strata | | | | Total; (N=49)
| GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
Number of Participants with Positive HSV Diagnostic Tests at End of Study | 1 (16.7%) | 1 (10.0%) | 6 (24.0%) | 0 | 8 (16.3%)
Participants with Positive HSV Diagnostic Tests by Type
HSV Viral Culture | 0 | 0 | 3 | 0 | 3
HSV DNA PCR | 1 | 1 | 3 | 0 | 5
Participants with Positive HSV Diagnostic Tests by Specimen Type
Blood | 1 | 0 | 2 | 0 | 3
Cerebrospinal fluid | 0 | 1 | 0 | 0 | 1
Mouth | 0 | 0 | 1 | 0 | 1
Rectum | 0 | 0 | 1 | 0 | 1
Skin or mucous membrane lesions | 0 | 0 | 1 | 0 | 1
Participants with Positive HSV Diagnostic Tests by Finding Type
Herpes simplex virus (unspecified) | 0 | 0 | 1 | 0 | 1
Herpes simplex virus - 1 | 0 | 0 | 1 | 0 | 1
Herpes simplex virus - 2 | 1 | 1 | 4 | 0 | 6

Note: This table includes only results from the last reported HSV diagnostic test after the first date of reported IV acyclovir dosing.

Table 14.2.3.2.1 Summary of Positive HSV Diagnostic Tests at Baseline by Site Safety Population

| Site | | | | Total; (N=49)
| ▬; (N=13) | ▬; (N=9) | ▬; (N=20) | ▬; (N=7) | Total; (N=49)
Number of Participants with Positive HSV Diagnostic Tests at Baseline | 10 (76.9%) | 8 (88.9%) | 16 (80.0%) | 5 (71.4%) | 39 (79.6%)
Participants with Positive HSV Diagnostic Tests by Type
HSV Viral Culture | 1 | 5 | 3 | 0 | 9
HSV DNA PCR | 10 | 4 | 13 | 5 | 32
HSV direct immunofluorescence assay | 0 | 1 | 0 | 0 | 1
Participants with Positive HSV Diagnostic Tests by Specimen Type
Blood | 6 | 2 | 1 | 2 | 11
Cerebrospinal fluid | 6 | 3 | 7 | 1 | 17
Conjunctivae | 0 | 1 | 0 | 1 | 2
Mouth | 0 | 3 | 0 | 0 | 3
Naso/oropharynx | 2 | 1 | 2 | 1 | 6
Rectum | 1 | 0 | 4 | 1 | 6
Skin or mucous membrane lesions | 2 | 4 | 6 | 4 | 16
Participants with Positive HSV Diagnostic Tests by Finding Type
Herpes simplex virus (unspecified) | 1 | 0 | 4 | 2 | 7
Herpes simplex virus - 1 | 4 | 2 | 5 | 2 | 13
Herpes simplex virus - 2 | 6 | 6 | 8 | 1 | 21

Note: This table includes all positive HSV diagnostic tests collected on or before the date of first reported IV acyclovir dose.

Multiple types and findings of HSV diagnostic tests per participant may be reported at baseline.

Table 14.2.3.2.2 Summary of Positive HSV Diagnostic Tests at End of Study by Site Safety Population

| Site | | | | Total; (N=49)
| ▬; (N=13) | ▬; (N=9) | ▬; (N=20) | ▬; (N=7) | Total; (N=49)
Number of Participants with Positive HSV Diagnostic Tests at End of Study | 4 (30.8%) | 2 (22.2%) | 1 (5.0%) | 1 (14.3%) | 8 (16.3%)
Participants with Positive HSV Diagnostic Tests by Type
HSV Viral Culture | 0 | 2 | 1 | 0 | 3
HSV DNA PCR | 4 | 0 | 0 | 1 | 5
Participants with Positive HSV Diagnostic Tests by Specimen Type
Blood | 1 | 1 | 0 | 1 | 3
Cerebrospinal fluid | 1 | 0 | 0 | 0 | 1
Mouth | 0 | 1 | 0 | 0 | 1
Rectum | 1 | 0 | 0 | 0 | 1
Skin or mucous membrane lesions | 1 | 0 | 0 | 0 | 1
Participants with Positive HSV Diagnostic Tests by Finding Type
Herpes simplex virus (unspecified) | 0 | 0 | 1 | 0 | 1
Herpes simplex virus - 1 | 1 | 0 | 0 | 0 | 1
Herpes simplex virus - 2 | 3 | 2 | 0 | 1 | 6

Note: This table includes only results from the last reported HSV diagnostic test after the first date of reported IV acyclovir dosing.

Table 14.3.1.1 Summary of Study Doses by GA and PNA group Safety Population

| Age Strata | | | | Total; (N=49)
| GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
Mean Study Dose (mg/kg/day)
N | 6 | 10 | 25 | 8 | 49
Mean (SD) | 75.1 (45.0) | 76.9 (37.2) | 78.0 (77.8) | 61.4 (9.1) | 74.7 (59.5)
Median (Min, Max) | 74.7 (20.1 - 134.1) | 58.9 (46.7 - 161.8) | 58.8 (28.3 - 431.4) | 57.7 (51.9 - 79.6) | 58.8 (20.1 - 431.4)
Max Study Dose (mg/kg/day)
N | 6 | 10 | 25 | 8 | 49
Mean (SD) | 133.7 (77.6) | 102.3 (79.5) | 92.8 (79.3) | 75.0 (16.5) | 96.8 (72.5)
Median (Min, Max) | 160.3 (20.1 - 220.9) | 72.2 (59.4 - 318.2) | 61.2 (39.5 - 441.2) | 71.0 (58.7 - 95.8) | 77.3 (20.1 - 441.2)
Cumulative Study Dose (mg/kg)
N | 6 | 10 | 25 | 8 | 49
Mean (SD) | 2477 (2614) | 1554 (959) | 1621 (1603) | 1124 (248) | 1631 (1521)
Median (Min, Max) | 2211 (20 - 7178) | 1332 (140 - 3398) | 1319 (60 - 6471) | 1251 (558 - 1276) | 1292 (20 - 7178)
Duration of Study Treatment (days)
N | 6 | 10 | 25 | 8 | 49
Mean (SD) | 25 (22) | 20 (11) | 20 (16) | 19 (6) | 21 (14)
Median (Min, Max) | 25 (1 - 62) | 21 (3 - 43) | 21 (2 - 82) | 22 (7 - 22) | 22 (1 - 82)

Note: The summary is at participant level.

Table 14.3.1.2 Summary of Study Doses by Site Safety Population

| Site | | | | Total; (N=49)
| ▬; (N=13) | ▬; (N=9) | ▬; (N=20) | ▬; (N=7) | Total; (N=49)
Mean Study Dose (mg/kg/day)
N | 13 | 9 | 20 | 7 | 49
Mean (SD) | 49.2 (11.0) | 49.3 (13.5) | 109.5 (81.3) | 55.7 (9.9) | 74.7 (59.5)
Median (Min, Max) | 54.0 (30.0 - 60.4) | 57.3 (20.1 - 59.5) | 90.0 (28.3 - 431.4) | 58.7 (33.8 - 63.8) | 58.8 (20.1 - 431.4)
Max Study Dose (mg/kg/day)
N | 13 | 9 | 20 | 7 | 49
Mean (SD) | 61.4 (12.9) | 56.0 (13.5) | 147.8 (91.7) | 69.3 (10.5) | 96.8 (72.5)
Median (Min, Max) | 60.0 (39.5 - 80.1) | 60.2 (20.1 - 62.0) | 103.8 (60.0 - 441.2) | 65.0 (58.7 - 83.7) | 77.3 (20.1 - 441.2)
Cumulative Study Dose (mg/kg)
N | 13 | 9 | 20 | 7 | 49
Mean (SD) | 842 (784) | 904 (589) | 2437 (1835) | 1731 (1351) | 1631 (1521)
Median (Min, Max) | 540 (60 - 2540) | 1250 (20 - 1416) | 1880 (558 - 7178) | 1319 (609 - 4719) | 1292 (20 - 7178)
Duration of Study Treatment (days)
N | 13 | 9 | 20 | 7 | 49
Mean (SD) | 15 (13) | 16 (10) | 23 (12) | 31 (23) | 21 (14)
Median (Min, Max) | 10 (2 - 43) | 21 (1 - 28) | 22 (7 - 62) | 22 (18 - 82) | 22 (1 - 82)

Note: The summary is at participant level.