# 5 ETHICS

## 5.1 Institutional Review Board

The investigator ensured that the protocol was reviewed and approved by the appropriate Institutional Review Board (IRB) prior to the start of any study activities. The IRB was appropriately constituted and performed its functions in accordance with United States (US) Food and Drug Administration (FDA) regulations, the International Conference on Harmonisation’s Good Clinical Practice (ICH GCP) guidelines, and local requirements as applicable. Any amendments to the protocol received IRB approval prior to implementation of any changes made to the study design. Detailed IRB information is provided in Appendix 16.1.3.

During the retrospective chart review process, each participating site was required to meet regulatory and institutional requirements for the protection of confidentiality of participants. Each site permitted authorized representatives of the sponsor, its designees, and appropriate regulatory agencies to examine (and, when required by applicable law, to copy) clinical records for the purposes of quality assurance reviews, audits, and evaluation of the study safety and progress. To assist with chart review, data collection forms were derived from the electronic case report forms (eCRFs) and provided by The Emmes Corporation which served as the Data Coordinating Center (DCC).

Representatives were permitted access to all source data, which included, but was not limited to, hospital records, clinical charts, laboratory notes, pharmacy dispensing records, recorded data from automated instruments, copies or transcriptions certified after verification as being accurate and complete, and participant files and records kept at the pharmacy and at the laboratories.

## 5.2 Ethical Conduct of the Study

This study was conducted in accordance with the ethical principles originating from the Declaration of Helsinki and current GCP and in compliance with Federal, State and local regulatory requirements and in the Code of Federal Regulations (CFR) Title 21 Part 312, 21 CFR 50 and 21 CFR 56.

## 5.3 Participant Information, Consent, and Assent

No participants were enrolled in this protocol, thus no informed consent was required. Data obtained from the medical chart review may have contained protected health information (PHI) and were therefore coded so that participants were identified by code numbers and not by name. Data obtained from the Pediatrix database were de-identified as defined by the Health Insurance Portability and Accountability Act (HIPAA) Privacy Rule (45 CFR 164.514 (a) and (b)). Participant information collected in this study complied with the standards for protection of privacy of individually identifiable health information as promulgated by HIPAA and as mandated in Title 45 CFR Parts 160 and 164.

Appropriate and adequate provisions for ensuring participant privacy and data confidentiality was maintained by the participating investigators, their staff, the sponsor(s), and their agents. Data access was limited to study personnel and the data was stored on servers which had limited physical access (e.g., locked rooms) and limited electronic access (e.g., password controlled access to data, computers and, if applicable, networks). The study protocol, documentation, data, and all other information generated by this study were maintained in a secure manner and were kept confidential as required by law. No information concerning the study or the data were released to any third party without prior written approval of the sponsor.

Study records used in the Medical Chart Review, including medical and pharmacy records, were permitted to be reviewed in order to meet federal or state regulations. Reviewers may have included the FDA, IRB(s), the sponsor and its representatives, and the National Institutes of Health (NIH).