# Descriptive Supplementary Documents

- Study Protocol
- Manual of Operations
- Data Collection Instruments
- Codebook/Variable Dictionary
- Data Analysis Plan
- De-Identification Methodology
- ACY 02 Study Synopsis
- Acyclovir: Proposed Labeling Changes
- ACY 02 Clinical Study Report
- ACY 02 Pediatrix Dataset Report