# 16 APPENDICES

16.1 Study Information
  16.1.1 Protocol and Protocol Amendments
  16.1.2 Sample Case Report Form for Medical Chart Review
  16.1.3 Institutional Review Boards (IRBs) and Consent Information
  16.1.4 Description of Investigators
  16.1.5 Signature Page
  16.1.6 Listing of Study Drug Batch Numbers
  16.1.7 Randomization Scheme and Codes
  16.1.8 Audit Certificates
  16.1.9 Statistical Analysis Plan for Medical Chart Review
  16.1.10 Documentation of Inter-laboratory Standardization Methods and Quality Assurance Procedures
  16.1.11 Publications Based on the Study
  16.1.12 Important Publications Referenced in the Report
16.2 Participant Data Listings for Medical Chart Review
16.3 Case Report Forms for Participants with SAEs
16.4 Miscellaneous
  16.4.1 Pediatrix Report: Acyclovir Safety in Hospitalized Infants Analysis) (Analysis of the Pediatrix Database)
  16.4.2 Pediatrix Report - Supplemental Tables (S-1 through S-7)
  16.4.3 Description of Pediatrix Datasets
  16.4.4 Pediatrix Datasets
  16.4.5 Pediatrix Data Dictionary (Pediatrix_Define.pdf)
16.5 Datasets and Define.pdf
  16.5.1 Medical Chart Review Datasets
  16.5.2 Medical Chart Review Data Dictionary (ACY02_revised-define.pdf)

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/15895