# 4 Glossary of Abbreviations and Terms

Abbreviation: Definition
AE: Adverse Event
ALT: Alanine Transaminase
AST: Aspartate Transaminase
AUC: Area Under the Concentration-Time Curve
BPCA: Best Pharmaceuticals for Children Act
BUN: Blood Urea Nitrogen
C: Celsius
CBC: Complete Blood Count
CL: Clearance
C_max_: Maximum Concentration
CNS: Central Nervous System
CRF: Case Report Form
CSF: Cerebrospinal Fluid
CV%: Coefficient of variation
dL: Deciliter
D5W: 5% Dextrose in Water
DCC: Data Coordinating Center
DMC: Data Monitoring Committee
DNA: Deoxyribonucleic acid
DOL: Day of Life
EDC: Electronic data capture
ELBW: Extremely Low Birth Weight
FDA: Food and Drug Administration
F: Fahrenheit
g: Gram
GA: Gestational Age
GMP: Guanosine monophosphate
GTP: Guanosine triphosphate
HIPAA: Health Insurance Portability and Accountability Act
HSV: Herpes Simplex Virus
IRB: Institutional Review Board
I/O: In and Out Catheterization
IV: Intravenous
Kg: Kilogram
µg: Microgram
mg: Milligram
ml: Milliliter
μL: Microliter
μM: Micromolar
ng: Nanogram
NICHD: National Institute of Child and Human Development
NICU: Neonatal Intensive Care Unit
PCA: Post-conceptual age
PCR: Polymerase Chain Reaction
PHI: Protected Health Information
PK: Pharmacokinetic
PNA: Postnatal Age
PTN: Pediatric Trials Network
RBC: Red Blood Cell
SAE: Serious Adverse Event
SD: Standard deviation
SOC: Standard of Care
t_1/2_: Terminal Elimination Half-Life
T_max_: Time of Maximum Concentration
V: Volume of Distribution
V_ss_: Volume of Distribution at Steady State
VLBW: Very Low Birth Weight
WBC: White Blood Cell