# 2 Synopsis

NAME OF IND SPONSOR:

P Brian Smith, MD, MPH, MHS

NAME OF STUDY DRUG:

Acyclovir

TITLE OF STUDY: An Open Label Study to Describe the Pharmacokinetics of Acyclovir in Preterm and Term Infants

PRINCIPAL INVESTIGATORS: P. Brian Smith, MD, MPH, MHS

Danny Benjamin, MD, MPH, MHS

Duke University Medical Center

PUBLICATION: Sampson MR, Bloom BT, Lenfestey RW, . Population pharmacokinetics of intravenous acyclovir in preterm and term infants. Pediatr Infect Dis J. 2014;33(1):42–49. doi:10.1097/01.inf.0000435509.75114.3d 24346595

STUDY PERIOD:

(date of first enrollment): September 19, 2011

(date of last completed): June 4, 2012

PHASE OF DEVELOPMENT: Phase 1

PRIMARY OBJECTIVE: Assess the PK of IV acyclovir in preterm and term infants.

METHODOLOGY:

The safety and PK of IV acyclovir in preterm and term infants with suspected systemic infections was evaluated. Thirteen participants were enrolled under version 1.0 of the protocol, which divided participants into 4 groups based on GA and PNA. Nineteen participants were enrolled under version ≥2.0 of the protocol, which divided participants into 3 groups based on GA and PNA. PK and safety data from infants enrolled under version 1.0 of the protocol were included in the final analysis.

Version 1.0 Group | Gestational Age | Postnatal Age | Dosage
1 | 23-29 weeks | < 14 days | 500 mg/m^2^ IV q8h
2 | 30-42 weeks | < 14 days | 500 mg/m^2^ IV q8h
3 | 23-29 weeks | 14-60 days | 500 mg/m^2^ IV q8h
4 | 30-42 weeks | 14-60 days | 500 mg/m^2^ IV q8h

Version >2.0 Group | Gestational Age | Postnatal Age | Dosage
1 | 23-29 weeks | < 14 days | 10 mg/kg IV q12h
2 | 23-29 weeks | 14-44 days | 20 mg/kg IV q12h
3 | 30-34 weeks | <45 days | 20 mg/kg IV q8h

NUMBER OF PARTICIPANTS (PLANNED AND ANALYZED):

Planned: approximately 20 evaluable (with at least 3 PK samples and qualify for 1 of the 3 groups defined by protocol version ≥2.0)

Analyzed: 32 for safety analysis and 30 in PK population (28 included in final PK analysis).

DIAGNOSIS AND MAIN CRITERIA FOR INCLUSION:

Inclusion Criteria:

The investigator or other study site personnel documented in the source documents (e.g., the hospital chart) that informed consent was obtained. Laboratory tests or non-pharmacologic treatment procedures that were performed as standard of care within 72 hours prior to first dose of study drug were in some cases, used for screening procedures and recorded in the CRF.

1. < 45 days of postnatal age and < 34 weeks gestational age at the time of initial study drug administration.
2. Sufficient venous access to permit administration of study medication.
3. Availability and willingness of the parent/legal guardian to provide written informed consent.
4. Suspected HSV sepsis
  - OR
  - At least two (2) of the following
    - Signs of sepsis AND negative blood cultures for >24 hours^1^
    - Respiratory distress^2^
    - Lethargy^2^
    - Fever ≥ 38.0°C^1^
    - Skin lesions^1,2^
    - Seizures (clinical OR EEG confirmed)^1^
    - Irritability^1^
    - AST OR ALT >2 X upper limit of normal^1,2^
    - >20 WBCs/µL or >500 RBCs/µL^1^ in CSF

Exclusion Criteria:

1. History of anaphylaxis attributed to acyclovir.
2. Serum creatinine >1.7 mg/dL.
3. Urine output <0.5 mL/kg/hour over the previous 12 hours
4. Previous participation in the study.
5. Concomitant condition, which in the opinion of the investigator would preclude a participant’s participation in the study.

TEST PRODUCT, DOSE AND MODE OF ADMINISTRATION, BATCH NUMBER:

Each 500 mg vial of acyclovir was initially reconstituted in 10 mL of sterile water for injection to an initial concentration of 50 mg/mL. A 7 mL aliquot of this solution was then added to 43 mL of D5W to produce a final concentration of 7 mg/mL. Study drug for all participants were infused in dextrose in water over one hour.

The batch numbers of a cyclovir used were as follows

▬: Manufacturer – APP Pharmaceuticals 6002601, 2022217, 6001659, 6002292, 6002602, 6002846, 6003538

▬: Manufacturer – Hospira Inc. 14007JT, 02107JT, 09147JT, 13145JT, 11088JT, 13139JT, 12108JT

Duration of Treatment:

The dose was administered every 8-12 hours for a total of 6-9 doses (3 days).

Reference Therapy, Dose and Mode of Administration, Batch Number:

Not Applicable

CRITERIA FOR EVALUATION:

Efficacy: Not Evaluated

Safety:

1. Serious Adverse Events
2. Adverse Events
3. Laboratory determinations

Pharmacokinetic:

1. Clearance (CL)
2. Volume of distribution (V)
3. Half-life (t_1/2_)
4. Steady-state peak concentration (Cmax_ss_)
5. Steady-state concentration at 50% of the dosing interval (C50_ss_)
6. Steady-state trough concentration (Cmin_ss_)

STATISTICAL METHODS:

Population Analyzed: All participants who received at least one dose of acyclovir. Data from participants enrolled under version 1 of this protocol at ▬ were included in the PK and safety analysis.

Statistical Methodology: Descriptive statistics such as number of observations, mean, median, 95% confidence interval, standard deviation, standard error, minimum, and maximum are presented for continuous variables (such as age, weight, etc.). Other descriptive statistics such as counts, proportions, and/or percentages were presented by gestational age and post-natal age groups to summarize discrete variables (such as race, sex, etc.).

Demographics and Baseline Characteristics: The number of participants completed, and discontinued early from study, and the reasons for discontinuation were summarized. Demographic and baseline characteristics are also summarized. Variables include race, age, sex, and selected clinical variables recorded prior to initiation of study drug. Study drug administration is summarized in terms of number of days of dosing, and reasons for final discontinuation of study drug.

Safety and Clinical Laboratory Analyses: Laboratory data, such as hematology and serum chemistry data as well as safety data were analyzed by postnatal and gestational age groups. Summary statistics for changes from baseline are presented. Continuous laboratory measurements are described at each visit using univariate descriptive statistics (mean, median, etc.); observed values and changes from baseline are summarized.

Pharmacokinetic Analysis: Population pharmacokinetic (PK) analysis was performed using NONMEM 7. Weight was included a priori as a significant covariate for clearance (CL) and volume of distribution (V). The following covariates were evaluated for relationships with PK parameters: serum creatinine (SCR), PNA, GA at birth, postmenstrual age (PMA), race, ethnicity, sex, and use of vasopressin, dopamine (DOPA), and epinephrine (EPI). A 2-stage approach was used to assess the impact of covariates: univariate forward inclusion followed by multivariate backwards elimination. Models were evaluated using goodness-of-fit plots, bootstrap methods, and visual predictive check (VPC). Empirical Bayesian estimates of individual participant PK parameters were generated from the final model using the post-hoc subroutine.

Determination of Sample Size: The sample size was based on the ability to describe the PK of acyclovir and to estimate the serious toxicity rate in participants. A sample size of 20 evaluable participants was expected to provide adequate precision in the PK parameter estimates (i.e. CL) that was dependent on the underlying variability of the parameter. The sample size provided reasonable estimates and 95% CI for safety. If one infant has an adverse event, then the 95% CI (exact binomial) for that AE within the the goal to link the final PK data with published PK data obtained from term infants.

RESULTS

Efficacy: N/A

Safety: Acyclovir was well tolerated in this open-label study of 32 infants. This cohort represented a group of critically ill infants with a history of the following conditions: 78.1% of the participants had a history of respirator, thoracic and mediastinal disorders; 37.5% had a history of nervous system disorders; and 18.8 had a history of metabolic acidosis.

Overall, 38 AEs were reported in 66% of the participants. The proportion of infants with AEs was highest, (90%), among infants with PNA<14 days and GA 23-29 weeks. Only 1 AE was considered related to study drug (worsening serum creatinine). A total of 4 SAEs were reported in 4 infants (13%). The proportion of infants with SAEs was higher for infants 35-41 weeks gestation (38%). Two of the SAEs were infant deaths. None of the SAEs were determined to be related to study drug. One death was due to a diagnosis of nonketotic hyperglycinaemia and one was due to sepsis.

Pharmacokinetics: A total of 81 timed plasma PK samples from 28 infants were used in the population PK analysis. Data were appropriately characterized by characterized by one compartment model using the one compartment model using the First Order Conditional Estimation method with ETA-EPS interaction (FOCEI) in NONMEM 7. Weight was included a priori as covariates for CL and V. The covariate screen revealed that PMA was significantly associated with acyclovir CL. No covariates other than weight were associated with V. The final model was: CL (L/h/kg) =0.305 * (PMA/31.3)^3.02^; V (L/kg) = 2.8. The between participant variability for CL and V were 53% and 85%, respectively. This final model appropriately characterized the data, and PK parameters were precise when evaluated during bootstrapping and visual predictive check. A new dosing strategy based on PMA was developed to account for developmental changes in acyclovir disposition.

CONCLUSIONS:

Primary Endpoint: PK

The final population PK model is:

- CL (L/h/kg) = 0.305 * (PMA/31.3)^3.02^
- V (L/kg) = 2.8

At the following doses, simulated acyclovir exposures in infants are similar to observed adult exposures, and the surrogate PD target (steady state concentrations for 50% of dosing interval ≥3 mg/L) is achieved in 91% of infants ≤41 weeks PMA:

- 20 mg/kg q12 hours in infants <30 weeks PMA
- 20 mg/kg q8 hours in infants 30-<36 weeks PMA
- 20 mg/kg q6 hours in infants 36-41 weeks PMA

Secondary Endpoint: Safety

Overall, acyclovir was well tolerated in this small cohort of critically ill premature infants. Only one AE was related to study drug (worsening creatinine)