# 13 Discussion and Overall Conclusions

## Primary Endpoint: PK

The final population PK model is:

- CL (L/h/kg) = 0.305 * (PMA/31.3)^3.02^
- V (L/kg) = 2.8

At the following doses, simulated acyclovir exposures in infants are similar to observed adult exposures, and the surrogate PD target (steady state concentrations for 50% of dosing interval ≥3 mg/L) is achieved in 91% of infants ≤41 weeks PMA:

- 20 mg/kg q12 hours in infants <30 weeks PMA
- 20 mg/kg q8 hours in infants 30-<36 weeks PMA
- 20 mg/kg q6 hours in infants 36-41 weeks PMA

## Secondary Endpoint: Safety

Overall, acyclovir was well tolerated in this small cohort of critically ill preterm and term infants. Only one AE was related to study drug (worsening creatinine).