# 12 Safety Evaluation

## 12.1 Extent of Exposure

The extent of exposure to study medication is summarized along with PK results, in Section 11.4.4. Listings of study drug administration for individual participants are provided in Section 16, Listing 16.2.6.

## 12.2 Adverse Events and Tolerability

An AE is any reaction, side effect, or other untoward medical occurrence, regardless of the relationship to study drug, which occurs during the conduct of a clinical trial. As all participants in this study had preexisting medical conditions and were hospitalized, those pre-existing conditions were not considered to be AEs. New events that occurred or worsened through frequency or intensity of pre-existing conditions were reported as AEs within the context of this study. A suspected adverse reaction is any AE for which there is a reasonable possibility that the drug caused the AE.

A serious adverse event or serious suspected adverse event as determined by the Investigator or the sponsor is any event that results in any of the following outcomes:

1. Death
2. Life-threatening AE (Life-threatening means that the study participant was, in the opinion of the investigator or sponsor, at immediate risk of death from the reaction as it occurred.)
3. Inpatient hospitalization or prolongation of existing hospitalization
4. Persistent or significant incapacity or substantial disruption of the ability to conduct normal life functions
5. Congenital abnormality or birth defect
6. Important medical event that may not result in one of the above outcomes, but may jeopardize the health of the study participant or require medical or surgical intervention to prevent one of the outcomes listed in the above definition of serious event.

All AEs were recorded from the time of administration of first dose of study drug through 3 days following last dose of study drug. All suspected adverse reactions, adverse reactions, and all serious events (SAEs, serious suspected adverse reactions and serious adverse reactions), were recorded from time of first study drug administration through 10 days post last study drug administration. All adverse events were coded using MedDRA version 15.0.

One reported AE occurred before the first dose of study drug. This participant [▬] had severe neonatal asphyxia and also received standard of care acyclovir before the first study dose. This event is included in the tables, participant profile graphs and the participant listings.

### 12.2.1 Summary of Adverse Events

An overall summary of tolerability is shown in Table 12-1. Overall, 38 AEs were reported in 21 of the 32 safety participants (66%) during the study. Nine (90%) of the 10 participants in Group 1 (GA 23-29 weeks/PNA < 14 days) had at least one AE; this group accounted for 24 of the 38 AEs. Three (60%) of the 5 participants in Group 2 (GA 23-29 weeks/PNA 14-44 days) reported one AE each. For Group 3 (GA 30-34 weeks/PNA <45 days), 6 AEs were reported in 5 (56%) of the 9 participants and 4 (50%) of 8 participants reported a total of 5 AEs in Group 4 (GA 35-42 weeks/PNA <14 days)). The maximum severity of any AE was mild or moderate for 17 participants (53%) and severe for 4 participants (13%). One AE was considered related to study drug; the participant [▬] had a worsening serum creatinine that lead to discontinuation of study drug..

Table 12-1 Overall Summary of Tolerability

Safety Population | GA 23-29 weeks; PNA <14 days; (n=10) | GA 23-29 weeks; PNA 14-44 days; (n=5) | GA 30-34 weeks; PNA <45 days; (n=9) | GA 35-42 weeks; PNA <14 days; (n=8) | Total; (n=32)
Number of AEs; Participants with at least one AE | 24; 9 (90%) | 3; 3 (60%) | 6; 5 (56%) | 5; 4 (50%) | 38; 21 (66%)
Participants with at Least One AE by Severity^1^; Mild; Moderate; Severe | 5 (50%); 3 (30%); 1 (10%) | 1 (20%); 2 (40%); 0 | 4 (44%); 1 (11%); 0 | 1 (13%); 0; 3 (38%) | 11 (34%); 6 (18.8%); 4 (12.5%)
Participants with at Least One AE by Causality^2^; Unrelated; Related | 8 (80%); 1 (10%) | 3 (60%); 0 | 5 (56%); 0 | 4 (50%); 0 | 20 (63%); 1 (3%)

1 Participants are counted only once at the greatest severity.

2 Participants are counted only once at the strongest relationship to study drug (causality).

Table 12-2 presents a summary of SAEs, participant deaths and study drug discontinuations. Four SAEs were reported in 4 participants (13%) including two deaths as described in Section 12.3.1. The other two SAEs include neonatal asphyxia in ▬, a life-threatening event occurring before the first study dose and neuroblastoma, an important medical event in ▬. Narratives for the reported SAEs are provided in Section 14, Table 14.3.6. Two AEs lead to study drug discontinuation: a worsening of serum creatinine possibly caused by the study drug in participant ▬, and SAE neuroblastoma in participant ▬ (not related to study drug).

Table 12-2 Summary of SAEs, Participant Deaths and Study Drug Discontinuation

Safety Population | GA 23-29 weeks; PNA <14 days; (n=10) | GA 23-29 weeks; PNA 14-44 days; (n=5) | GA 30-34 weeks; PNA <45 days; (n=9) | GA 35-42 weeks; PNA <14 days; (n=8) | Total; (n=32)
Number of SAEs; Participants with at least one AE; Participants with AE leading to stopping study drug; Participant deaths | 1; 1 (10%); 1 (10%); 1 (10%) | 0; 0; 0; 0 | 0; 0; 0; 0 | 3; 3 (38%); 1 (13%); 1 (13%) | 4; 4 (13%); 2 (6%); 2 (6%)

### 12.2.2 Display of Adverse Events

AE and SAE data are presented in the following tables:

- Overall summary of AEs by GA/PNA Group in Section 14, Table 14.3.1.1.
- Summary of AEs by MedDRA System Organ Class, Preferred Term and GA/PNA Group in Section 14, Table 14.3.1.2.1
- Summary of SAEs by MedDRA System Organ Class, Preferred Term and GA/PNA Group in Section 14, Table 14.3.1.2.2.
- Summary of Deaths by MedDRA System Organ Class, Preferred Term and GA/PNA Group in Section 14, Table 14.3.1.2.3.
- Summary of AEs by MedDRA System Organ Class, Preferred Term, Severity and GA/PNA Group in Section 14, Table 14.3.1.3.
- Summary of AEs by MedDRA System Organ Class, Preferred Term, Relationship to study medication and GA/PNA Group in Section 14, Table 14.3.1.4.
- AEs listed by MedDRA System Organ Class, Most Frequent Preferred Term and GA/PNA Group in Section 14, Table 14.3.1.5.

Individual patient data associated with AEs are listed in Section 16 as follows:

- All AEs (Listing 16.2.8.1),
- All SAEs (Listing 16.2.8.2),
- AEs resulting in death (Listing 16.2.8.3)

### 12.2.3 Analysis of Adverse Events

#### 12.2.3.1 Most Frequently Reported Adverse Events

The most frequently reported AEs were adrenal insufficiency (3 participants, 9%) and patent ductus arteriosus (3 participants, 9%). All of these adverse events occurred in the youngest age group (GA 23-29 weeks/PNA <14 days). All other AEs occurred in < 3 participants. See Table 12-3 and Table 14.3.1.5.

Table 12-3 Most Frequently Occurring (> 3 Participants) AE

Safety Population | GA 23-29 weeks; PNA <14 days; (n=10) | GA 23-29 weeks; PNA 14-44 days; (n=5) | GA 30-34 weeks; PNA <45 days; (n=9) | GA 35-42 weeks; PNA <14 days; (n=8) | Total; (n=32)
Participants with at least one AE | 9 (90%) | 3 (60%) | 5 (56%) | 4 (50%) | 21 (66%)
Endocrine disorders; Adrenal insufficiency | 3 (30%) | 0 | 0 | 0 | 3 (9%)
Congenital, familial and genetic disorders; Patent ductus arteriosus | 3 (30%) | 0 | 0 | 0 | 3 (9%)

#### 12.2.3.2 Adverse Events by Intensity

AEs had severity graded as mild, moderate and severe. Twenty six (68%) of the 38 AEs were reported as mild, 8 (21%) were reported as moderate and 4 (11%) were reported as severe. These 4 severe AEs, which were further described as 1 important medical event, 1 life-threatening and 2 resulting in death were reported as SAEs.

#### 12.2.3.3 Adverse Events by Relationship

One AE of worsening serum creatinine was determined to be caused by the study drug with reasonable possibility. The study drug was permanently stopped for this participant. All other AEs were considered to be unrelated to study drug.

### 12.2.4 Listing of Adverse Events by Participant

A complete listing of all AEs is provided in Section 16, Listing 16.2.8.1.

## 12.3 Deaths and Serious Adverse Events

### 12.3.1 Deaths

Two deaths have been reported in this study. One event (▬) was described as nonketotic hyperglycinaemia, occurring 8 days post birth and described as unrelated to study medication by the site PI. Another event (▬) was reported as sepsis and was unrelated to the study medication as reported by the site PI.

### 12.3.2 Serious Adverse Events

Four (13%) of the 32 participants, each had at 1 SAE. Three of the 4 participants were in the GA 35-42 weeks/PNA <14 days group and enrolled under version 1 of the protocol. These 3 SAEs included the death of participant ▬ with nonketotic hyperglycinaemia described above, participant ▬ reporting life-threatening neonatal asphyxia and participant ▬ with a neurblastoma. The fourth SAE was death of participant ▬; this participant died from sepsis, was in group GA 23-29 weeks/PNA <14 days and enrolled under protocol version ≥ 2. See SAE narratives in Section 14.3.6 for complete reports.

## 12.4 Clinical Laboratory Evaluations

Descriptive summaries (mean, standard deviation (SD), median, minimum, and maximum) of observed values at baseline, each dosing day, and change from baseline to last dosing day are presented for hematology and chemistry clinical laboratory values by GA/PNA groups in tables and overall in box plots. Measurements were collected, per standard of care, within 72 hours prior to first study dose (baseline) through 24 hours following the last dose of study drug.

Hematology/differential measurements of white blood count, hematocrit, platelet count, neutrophils, lymphocytes and bands are presented in Table 14.3.2.1.1-14.3.2.1.6. Figure 14.3.1.1-14.3.1.6 presents box plots of measurements at baseline, first dosing day, last dosing day and change from baseline to last dosing day with the GA/PNA groups combined. The box represents the 25th and 75th percentiles, the whiskers are drawn to the 5th and 95th percentiles, stars represent outliers, the horizontal line is the median and the triangle represents the mean value.

Similarly, results are presented for chemistry measurements of creatinine, BUN, AST, ALT, alkaline phosphatase, total bilirubin, direct bilirubin, sodium, potassium, calcium and albumin in Table 14.3.2.2.1-14.3.2.2.11 and as box plots in Figure 14.3.2.1-14.3.2.11 as described above.

Figure 12-1 presents serum creatinine measurements (with mean ± SD) by GA/PNA group over the course of the study. At baseline (pre-dose) the mean serum creatinine level was 1.1 mg/dL for the 10 participants in Group 1 (GA 23-29 weeks/PNA<14 days). The mean serum creatinine level after the last study dose of acyclovir in the 7 participants with the last dose measurement increased to 1.4 mg/dL. Group 2 (GA 23-29 weeks/PNA 14-44 days) participants had a mean of 1.13 mg/dL at baseline and a mean 0.70 mg/dL after the last dose of study drug. Group 3 (GA 30-34 weeks/PNA <45 days) participants had a mean measurements of 0.8 mg/dL at baseline and a mean 0.8 mg/dL on the last dosing day. Serum creatinine measurements in Group 4 (GA 35-42 weeks/<14 days) participants decreased from a mean of 0.8 mg/dL at baseline to 0.6 mg/dL after the last dose. Not all participants had measurements at all time points.

Figure 12-1 Serum Creatinine by GA/PNA Group

Data for many of the laboratory measurement was too sparse to draw conclusions; however, each value was reviewed by the site PI to determine clinical significance. Laboratory measurements that were determined to be clinically significant were entered as AEs if they began after the first study drug administration and were not otherwise reported as part of a larger diagnosis. Before data lock, the laboratory data for each participant was also reviewed by the study PI, who determined if further follow up regarding clinical significance was necessary.

## 12.5 Vital Signs, Physical Examinations and Other Observations Related to Safety

### 12.5.1 Weight

Participants lost a median of 10 g over the course of the study from a median of 1400 g at baseline to a median of 1282 g on the last dosing day. The participants in Group 1 (GA 23-29 weeks/PNA<14 days) lost a median of 8 g (from 810 at baseline to 732 g on the last dosing day), the participants in Group 2 (GA 23-29 weeks/PNA 14-44 days) gained a median of 57 g (from 810 to 895 g). Group 3 (GA 30-34 weeks/PNA <45 days) participants lost a median of 64 g (from 1770 to 1650 g), and Group 4 (GA 35-42 weeks/<14 days) participants had a median weight change of 0.

Median dosing weight was 805 g (range 420 to 1270 g) at the first study dose for Group 1 (GA 23-29 weeks/PNA<14 days), 810 g (range 630 to 1045 g) for Group 2 (GA 23-29 weeks/PNA 14-44 days), 1770 g (range 800 to 2645 g)for Group 3 (GA 30-34 weeks/PNA <45 days) and 3138 g (range 1980 to 4840 g)for Group 4 (GA 35-42 weeks/<14 days). Most participants were treated at the same dosing weight throughout the course of the study.

### 12.5.2 Concomitant Medications

Administration of inotropes and probenecid within 72 hours prior to the first dose of study drug through 24 hours following last dose of study drug were recorded. These concomitant medications were coded according to the WHO (World Health Organization) drug classification system version March 2012. Medications starting before the first day of study acyclovir are presented in Table 14.3.4.1. Four participants received dopamine with one of those participants also receiving epinephrine. Concomitant medications received during study acyclovir treatment are reported in Table 14.3.4.2. This includes both medications started on the same day study drug began and medications started before, but continuing on or after the day study drug began. Four participants (13%) received dopamine only, 3 participants received dopamine and epinephrine and 1 participant received dopamine, epinephrine and vasopressin.

### 12.5.3 Physical Examination

Physical examination was used to record any non-clinically significant abnormal symptoms or diseases that were newly diagnosed or worsened since informed consent (or last visit). Table 14.3.5 summarizes these abnormal systems during the course of the study. Overall, 23 (72%) of the 32 participants reported at least one abnormal system: 9 (90%) of Group 1 (GA 23-29 weeks/PNA <14 days), 5 (100%) of Group 2 (GA 23-29 weeks/PNA 14-44 days), 7 (78%) of Group 3 (GA 30-34 weeks/PNA <45 days) and 2 (25%) of Group 4 (GA 35-42 weeks/PNA <14 days) participants. Eighteen (56%) participants reported abnormalities in each of general appearance and blood/lymphatic systems and 17 (53%) reported abnormalities in respiratory systems.

## 12.6 Safety Conclusions

Acyclovir was well tolerated in this open-label study of 30 infants. This cohort represented a group of critically ill infants with a history of the following conditions: 78.1% of the participants had a history of respiratory, thoracic and mediastinal disorders; 37.5% had a history of nervous system disorders; and 18.8 had a history of metabolic acidosis.

Overall, 38 AEs were reported in 66% of the participants. The proportion of infants with AEs was highest, (90%), among infants with PNA<14 days and GA 23-29 weeks. Only 1 AE was considered related to study drug (worsening serum creatinine). A total of 4 SAEs were reported in 4 infants (13%). The proportion of infants with SAEs was higher for infants 35-41 weeks gestation (38%). Two of the SAEs were infant deaths. None of the SAEs were determined to be related to study drug. One death was due to a diagnosis of nonketotic hyperglycinaemia and one was due to sepsis.