# 11 Efficacy and PK Evaluation

The primary objective of this study was to assess the PK of IV acyclovir in preterm and term infants. The efficacy of acyclovir was not investigated in this study. However, microbiological cultures during acyclovir therapy were recorded if obtained per routine medical practice and are reported in this section.

## 11.1 Datasets Analyzed

A total of 32 participants were enrolled in this study; all participants received study acyclovir and are included in the safety population. Thirty participants had at least one fresh timed plasma PK samples drawn and are included in the PK analysis population. Thirty of the 32 participants had at least one sample drawn for testing for microbial cultures and were reviewed for infection status.

## 11.2 Demographic and Other Baseline Characteristics

Baseline demographics for the Safety Population are presented in Table 11-1 and Table 14.1.2.1. Median GA is 26 weeks and median PNA was 3.5 days for Group 1 (GA 23-29 weeks/PNA <14 days), median GA of 24 weeks and PNA of 22 days for Group 2 (GA 23-29 weeks/PNA 14-44 days), median GA of 33 weeks and PNA of 2 days Group 3 (GA 30-34 weeks/PNA <45 days) and Group 4 (GA 35-42 weeks/PNA <14 days) had a median GA of 38 weeks and PNA of 2 days. The total population had a median GA of 30.5 weeks and median PNA of 3 days.

Fifteen (47%) participants were male. Twenty (63%) were of Caucasian descent, 11 (34%) were Black and 1 was Asian. Four (13%) participants were reported to be Hispanic or Latino. Note that in Version 1 participants, only maternal race and ethnicity was collected.

Table 11-1 Participant Demographic Characteristics

Participant Demographics | GA 23-29 weeks; PNA <14 days; (n=10) | GA 23-29 weeks; PNA 14-44 days; (n=5) | GA 30-34 weeks; PNA <45 days; (n=9) | GA 35-42 weeks; PNA <14 days; (n=8) | Total; (n=32)
Gestational age (weeks); Mean (SD); Median (Min, Max) | 26.2 (1.8); 26 (24, 29) | 23.6 (0.5); 24 (23, 24) | 32.6 (1.6); 33 (30, 34) | 37.5 (2.0); 38 (35, 40) | 30.4 (5.5); 30.5 (23, 40)
Postnatal age (days); Mean (SD); Median (Min, Max) | 5.2 (3.8); 3.5 (1, 12) | 20.8 (6.5); 22 (14, 30) | 3.6 (5.1); 2 (0, 16) | 2.5 (2.5); 2 (0, 8) | 6.5 (7.6); 3 (0, 30)
Gender; Male; Female | 2 (20%); 8 (80%) | 3 (60%); 2 (40%) | 5 (56%); 4 (44%) | 5 (63%); 3 (38%)3 (38%) | 15 (47%); 17 (53%)
Ethnicity^*^; Hispanic or Latino | 2 (20%) | 1 (20%) | 1 (11%) | 0 | 4 (13%)
Race^*^; Asian; Black or African American; White or Caucasian | 0; 5 (50%); 5 (50%) | 0; 2 (40%); 3 (60%) | 0; 2 (22%); 7 (78%) | 1 (13%); 2 (25%); 5 (63%) | 1 (3%); 11 (34%); 20 (63%)

* Version 1.0 participants reported maternal race and ethnicity; version >2.0 participants reported participant race and ethnicity.

The median birth weight is 790 g (range 420 to 1270 g) and 630 g (range 510 to 914 g) for the GA 23-29 weeks groups (Groups 1 and 2 respectively). The median birth weight is 1770 g (range 800 to 2645) for the GA 30-34 week group and 3138 g (range 1980 to 4840) in the 35-42 week GA group.

Baseline medical history is presented in Table 11-2 and Table 14.1.2.2 by MedDRA system, versions 14.1 and 15.0, organ class and preferred term. Table 11-2 lists the most frequently occurring preferred terms (in >15% of the participants). Fifty-three percent of the participants had a history of neonatal respiratory distress syndrome, 44% had infantile apneoic attack and history of prematurity.

Table 11-2 Baseline Medical History, Most Frequently Occurring (>15% of the Participants) Preferred Terms

System Organ Class; Preferred Term | GA 23-29 weeks; PNA <14 days; (n=10) | GA 23-29 weeks; PNA 14-44 days; (n=5) | GA 30-34 weeks; PNA <45 days; (n=9) | GA 35-42 weeks; PNA <14 days; (n=8) | Total; (n=32)
Respiratory, thoracic and mediastinal disorders; Neonatal respiratory distress syndrome; Infantile apnoeic attack | 8 (80%); 4 (40%) | 5 (100%); 4 (80%) | 3 (33%); 5 (56%) | 1 (13%); 1 (13%) | 17 (53%); 14 (44%)
Pregnancy, puerperium and perinatal conditions; Premature baby | 8 (80%) | 0 | 6 (67%) | 0 | 14 (44%)
Hepatobiliary disorders; Hyperbilirubinaem ia | 3 (30%) | 5 (100%) | 2 (22%) | 2 (25%) | 12 (38%)
Vascular disorders; Hypotension | 4 (40%) | 4 (80%) | 1 (11%) | 2 (25%) | 11 (34%)
Nervous system disorders; Convulsion | 1 (10%) | 4 (80%) | 0 | 4 (50%) | 9 (28%)
Hepatobiliary disorders; Hyperbilirubinaem ia neonatal | 5 (50%) | 0 | 2 (22%) | 0 | 7 (22%)
Metabolism and nutrition disorders; Hyperglycaemia; Metabolic acidosis | 3 (30%); 1 (10%) | 2 (40%); 4 (80%) | 1 (11%); 0 | 0; 1 (13%) | 6 (19%); 6 (19%)
Congenital, familial and genetic disorders; Patent ductus arteriosus | 2 (20%) | 2 (40%) | 0 | 1 (13%) | 5 (16%)

## 11.3 Measurement of Treatment Compliance

All participants were inpatients in the hospital. Therefore, each dose of study drug administration was given and monitored by hospital staff, then reviewed by study personnel. The protocol provided guidelines for study medication dosing.

## 11.4 Efficacy Results and Tabulations of Individual Participant Data

### 11.4.1 Analysis of Efficacy

There were no planned efficacy analyses as part of this study. However, microbiological cultures obtained per routine medical care before and during acyclovir therapy are reported here.

#### Microbiology Cultures

At least one microbiology culture was obtained from 30 (94%) of the 32 participants within 72 hours of the 1^st^ dose of study drug through 24 hours after the last dose of study drug were recorded. A total of 85 cultures were obtained of which 30 were blood cultures, 19 were HSV surface cultures and 13 were MRSA nasal cultures. The remaining cultures included 9 CSF, 7 CSF PCR, 6 urine and 1 endotracheal suction bacteria culture. Detailed information on microbiology cultures is included in Section 16, Listing 16.2.11.

### 11.4.2 Statistical and Analytical Issues

#### 11.4.2.1 Adjustments for Co-Variates

There were no planned efficacy analyses; only PK of acyclovir was analyzed.

#### 11.4.2.2 Handling of Dropouts or Missing Data

The protocol allowed for participants with fewer than 3 samples to be replaced.

#### 11.4.2.3 Interim Analysis and Data Monitoring

No interim analyses were planned or completed for this study.

#### 11.4.2.4 Multi-Center Studies

The possible effects of study center were not investigated.

#### 11.4.2.5 Multiple Comparison/Multiplicity

Inferential statistical tests were not performed in this study.

#### 11.4.2.6 Use of an “Efficacy Subset” of Participants

The PK population included all participants who had at least one timed fresh plasma sample. Thirty of the 32 participants had at least one timed fresh plasma sample.

#### 11.4.2.7 Active-Control Studies Intended to Show Equivalence

This section does not apply to this report.

#### 11.4.2.8 Examination of Subgroups

Subgroups were not analyzed.

### 11.4.3 Tabulation of Individual Response Data

Individual participant data can be found in the Data Listings of Section 16, Appendix 16.2.

### 11.4.4 Drug Dose, Drug Concentration and Relationship to Response

#### 11.4.4.1 Dosing

Doses in this section are presented in ‘mg per kg’ of participants’ actual weight and are presented by dosing groups. See Table 10-1 for the dosing groups and Table 14.4.1 for dosing summary.

All version 1.0 participants were dosed at 500 mg/m^2^ IV every 8 hours (n=13) for up to 5 days. These participants received a median of 6 study doses (range 2 to 11). Median dose was 37.7 mg/kg (range 24.5 to 52.6 mg/kg). Eight (62%) were already receiving SOC acyclovir at the time of the first study dose. These 8 participants received between 1 and 8 SOC doses at a median dose of 39.1 mg/kg (range 28.9 to 52.6 mg/kg). None of these participants continued on SOC acyclovir after completing the study doses.

Version ≥2.0 participants were dosed at 10 mg/kg q12 hours in Group 1 (GA 23-29 weeks/PNA <14 days), 20 mg/kg q12 hours in Group 2 (GA 23-29 weeks/PNA 14-44 days) and 20 mg/kg q8 in Group 3 (GA 30-34 weeks/PNA <45 days). Participants were treated for up to 3 days and received a median of 6, 4 and 9 study doses for the Groups 1, 2, and 3, respectively. Median doses (range) were 10.6 mg/kg (9.3 to 38.5 mg/kg) for Group1, 18.7 mg/kg (8.9 to 21.2 mg/kg) in Group 2 and 21.2 mg/kg (19.6 to 46.8 mg/kg) in Group 3. Five version ≥2.0 participants were already receiving SOC acyclovir when they started on the study. They received a total of 12 doses ranging from 9.1 to 38.5 mg/kg. Five participants received SOC acyclovir after completing the study doses. These participants received a total of 6 doses ranging from 10.2 to 46.8 mg/kg.

#### 11.4.4.2 PK Sampling

One hundred and thirty nine (139) samples (in 30 participants) were collected during this study with a median of 4 PK samples per participant (Table 14.4.2). The 139 samples consisted of 92 timed fresh plasma samples, 35 scavenged plasma samples and 12 urine samples.

#### 11.4.4.3 PK Drug Concentration

Acyclovir was measured in each sample. Descriptive summary statistics of concentration values (mg/L) are reported in Table 14.4.3. Concentrations were further evaluated by sampling time windows as defined in the protocol; see Table 14.4.4 for timed plasma samples. Windows were defined by the protocol as shown in Table 11-3. For version 1.0 timed plasma samples, 32 of the 43 (74%) samples fell within the sampling windows shown above, with median acyclovir concentration from doses 5-15 of 4.8 mg/L immediately prior to dose, 12.8 mg/L 0-5 minutes after the dose, 15.4 mg/L 2-4 hours after the dose and 13.4 mg/L 6-8 hours after the dose.

Table 11-3 Dosing Windows

PK Sampling: Version 1.0 | | PK Sampling: Version ≥ 2.0
Dose 1 | 0-5 min after; 2-4 hours after; 6-8 hours after | Dose 1 | 0-15 min after; 30 min before dose 2
Dose 5 -Dose 15 | Immediately prior; 0-5 min after; 2-4 hours after; 6-8 hours after^*^ | Dose 5-6 & Group 1-2; OR; Dose 8-9 & Group 3 | 30 min prior OR 30 min prior to next dose; 0-15 min after; 2-3 hours after
| | Last Dose | 15-18 hours after

* Note: 6-8 hours after could also be immediately prior to next dose. Doses counted only once in 6-8 hour category.

Participants enrolled under version ≥2.0 had 21/49 (43%) fresh timed PK samples fall into the above windows. For steady-state doses (Dose 5-6 & Group 1-2 or Dose 8-9 & Group 3) median acyclovir concentration was 5.5 mg/L immediately prior to the dose, 10.3 mg/L 0-15 minutes after the dose and 4.8 mg/L 2-3 hours after the dose.

#### 11.4.4.4 Pharmacokinetic Analysis

##### 11.4.4.4.1 Population PK Analysis

Ninety-two timed plasma samples from 30 infants were measured. Nine (9.8%) samples were suspected to be drawn during infusion or flush and were excluded prior to model development. The final model was used to screen for extreme outlier concentrations (>10-fold difference from predicted concentration), suggesting sample contamination or other collection or dosing error. Two additional (2.2%) samples were identified as outliers and excluded after identification of the final model. This resulted in exclusion of 2 participants (each with 1 plasma sample). The final dataset included 81 samples from 28 infants. Participant demographics at the time of first PK sample are listed in listed in Table 11-4.

Table 11-4 Participant Demographics (N=28)

| Median (range) or (%)
GA (weeks) | 30.5 (23 - 40)
PNA (days) | 3.5 (1-30)
PMA (weeks) | 31.3 (25-41)
Weight (g) | 1370 (578-5720)
Male | 46%
SCR (mg/dL) | 0.9 (0.3-1.8)
Vasopressin use | 4%
Dopamine use | 14%
Epinephrine use | 25%

Data were fit to a one compartment model (ADVAN1 TRANS2) and the First Order Conditional Estimation method with ETA-EPS interaction (FOCEI). Weight (WTKG) was assumed to be a significant covariate for CL and V and was included in the base model prior to assessment of other potential covariates. A univariate covariate screen was performed for potential associations with PK parameters. Empiric Bayesian estimates of individual participant PK parameters were generated from the final model using the posthoc subroutine.

Plots of PMA, PNA, GA, and SCR were suggestive of a relationship with ETA CL; no covariates were suggestive of a relationship with ETA V other than weight. PMA was identified as the most significant age covariate for acyclovir CL. SCR was the only significant non-age covariate for CL. Addition of SCR to the PMA model did not significantly reduce the OFV. Thus the final model only includes weight and PMA as covariates for CL and weight as the only covariate for V. Selected model-building steps are summarized in Table 11-5.

Table 11-5 Summary of Steps in the Acyclovir Model-Building Process

Description | Population model | OFV | ΔOFV
V (all models) | V(L)=2.8*Weight | 1500.7 | -
CL base model | CL(L/h)=0.299*Weight | 1500.7 | -
PNA on CL | CL(L/h)=0.319*Weight*(PNA/3.5)^−0.161^ | 1498.0 | −2.7
SCR on CL | CL(L/h)=0.275*Weight*(0.9/SCR)^0.577^ | 1492.0 | −8.7
GA on CL | CL(L/h)=0.295*Weight*(GA/30.5)^2.35^ | 1481.7 | −19.0
PMA on CL | CL(L/h)=0.280*Weight*(PMA/31.3)^3.00^ | 1478.9 | −21.8
GA, PNA, and SCR on CL | CL(L/h)=0.283*Weight*(PNA/3.5)^−0.007^ *(0.9/SCRE)^0.441^*(GA/30.5)^2.16^ | 1476.2 | −24.5
PMA and SCR on CL | CL(L/h)=0.269*Weight*(0.9/SCR)^0.577^ *(PMA/31.3)^3.02^ | 1475.3 | −25.4
PMA on CL (2 outliers dropped) | CL(L/h)=0.305*Weight*(PMA/31.3)^3.02^ | 1408.5 | −92.2

Δ OFV is relative to the base model.

The final population model for acyclovir is:

- CL (L/h) = 0.305*Weight*(PMA/31.3)^3.02^*exp(η_CL_)
- V (L)= 2.8*Weight*exp(η_V_)

The final model predicts more than a 5-fold increase in CL from 23-40 weeks PMA. The inter-participant variability in CL and V for acyclovir in the base model was 72% and 90%, respectively, and 53% and 85% for the final model, respectively..

The median empirical Bayesian post-hoc parameter estimate for CL, 0.278 L/hr/kg, was within 10% of the typical population model estimate of 0.305 L/hr/kg. CL estimates increase, V estimates were unchanged, and t 1/2 estimates decreased with increasing PMA (Table 11-6 and Figure 11-1).

Table 11-6 Individual Empirical Bayesian Post-Hoc Parameter Estimates for Acyclovir

PMA | N | CL (L/h/kg) | V (L/kg) | t_1/2_ (h) | Cmax_ss_ (mg/L) | C50_ss_ (mg/L) | Cmin_ss_ (mg/L)
<30 | 13 | 0.211 (0.095-0.310) | 2.88 (0.646-5.30) | 10.2 (4.73-13.2) | 10.3 (4.59-110) | 7.12 (3.38-65.7) | 3.92 (2.38-39.3)
30 - <36 | 9 | 0.449 (0.302-0.812) | 4.49 (1.87-10.85) | 6.55 (4.28-9.26) | 8.83 (5.44-29.8) | 6.80 (3.72-16.9) | 5.10 (2.54-9.62)
36 - 41 | 6 | 0.589 (0.126-0.769) | 2.55 (0.293-4.09) | 3.00 (1.61-3.69) | 12.4 (10.8-86.1) | 5.82 (5.23-22.0) | 2.90 (2.19-7.46)
Overall | 28 | 0.278 (0.095-0.812) | 3.34 (0.293-10.85) | 7.07 (1.61-13.2) | 11.1 (4.59-110) | 6.33 (3.38-65.7) | 4.15 (2.19-39.3)

Data are median (range).

Figure 11-1 PK Parameters versus PMA (Age)

##### 11.4.4.4.2 PD Endpoints

The surrogate PD targets were steady-state plasma acyclovir peak (Cmax_ss_), concentration at 50% of the dosing interval (C50_ss_), and trough concentration (Cmin_ss_) ≥3 mg/L and ≥1 mg/L. These PD targets were chosen based on the HSV IC50 (1 mg/L) and reported acyclovir central nervous system (CNS) penetration of approximately 30–50%.^7,9^ Based on case report data in children and adults, surrogate safety targets of Cmax_55_ <50 and 70 mg/L were chosen to avoid potential toxicity.^7,10–12^ The proportion of infants achieving these targets was calculated. The final model was used to simulate acyclovir concentrations in 1000 infants randomly obtained from the Pediatrix Medical Group database.^13^ A PMA-based dosing regimen was compared with dosing regimens found in commonly used pediatric handbooks. The best regimen was chosen on the basis of maximizing achievement of the PD target and minimizing the fraction of infants with concentrations ≥50 mg/L.

##### 11.4.4.4.3 PD Endpoint Achievement

Trough acyclovir concentrations at steady state were predicted for each participant using the individual Bayesian estimates generated from the final population PK model and the dosing scheme evaluated in this study. Using the dosing infants received in the trials, 28/28 (100%) of infants had Cmax_ss_and C50_ss_≥3 mg/L. Cmin_ss_was ≥3 mg/L for 18/28 (64%) infants overall: 7/12 (58%) in version 1.0 and 11/16 (69%) in version ≥2.0. One hundred percent of infants had steady-state concentrations 2-fold greater than 1 mg/L (2 mg/L) throughout the dosing interval. Three out of 28 (10.7%) infants had Cmax_ss_ ≥50 mg/L; these infants were all in version 1.0 and received 31–53 mg/kg q8h.

A PMA-based dosing regimen was developed to account for developmental changes in acyclovir disposition:

- 20 mg/kg q12 hours in infants PMA <30 weeks
- 20 mg/kg q8 hours in infants PMA 30 to <36 weeks
- 20 mg/kg q6 hours in infants PMA 36-41 weeks

Monte Carlo simulations of this dose regimen predicted Cmax_ss_, C50_ss_, and Cmin_ss_≥3 mg/L for 98%, 91%, and 71% of infants, respectively, and ≥1 mg/L for all infants throughout the dosing interval; 0.9% and 0.3% of infants exceeded the surrogate safety targets of Cmax_ss_ >50 mg/L and 70 mgL, respectively (Table 11-7).

Table 11-7 PD Target Attainment for 1000 Infants from Pediatrix Database

| | % Participants ≥3 mg/L | | | % Participants ≥1 mg/L
PMA | N | Cmax_ss_ | C50_ss_ | Cmin_ss_ | Cmax_ss_ | C50_ss_ | Cmin_ss_
<30 | 218 | 100 | 97 | 89 | 100 | 100 | 100
30 - <36 | 373 | 98 | 94 | 75 | 100 | 100 | 100
36 - 41 | 409 | 96 | 86 | 56 | 100 | 100 | 100
Overall | 1000 | 98 | 91 | 71 | 100 | 100 | 100

Steady-state Cmax_ss_, C50_ss_, and Cmin_ss_were calculated from individual empirical Bayesian post-hoc parameter estimates. The PMA-based dosing regimen was then compared to regimens found in commonly used pediatric handbooks. None of the handbook dosing regimens consistently achieved C50_ss_≥3 mg/L for >90% of infants, and target attainment for Cmin_ss_was also reduced compared with PMA-based dosing (Table 11-8).

Table 11-8 Target Attainment Rate for Handbook Dosing Regimens

| | | | | % Participants >3mg/L
Handbook | Dose (mg/kg) and frequency (h) | GA (weeks) | PMA (weeks) | n | Cmax_ss_ | C50_ss_ | Cmin_ss_
FDA label | 10 q8 | Any | <30 | 218 | 95 | 91 | 81
FDA label | 10 q8 | Any | 30- <36 | 373 | 80 | 53 | 15
FDA label | 10 q8 | Any | 36-41 | 409 | 66 | 18 | 0
FDA label | 10 q8 | Overall | | 1000 | 77 | 47 | 23
Redbook and Lexicomp | 20 q8 | any | <30 | 218 | 100 | 100 | 100
Redbook and Lexicomp | 20 q8 | any | 30 - <36 | 373 | 98 | 94 | 74
Redbook and Lexicomp | 20 q8 | any | 36-41 | 409 | 94 | 70 | 10
Redbook and Lexicomp | 20 q8 | any | <41 | 1000 | 97 | 85 | 53
Harriet Lane | 20 q12 | <34 | NA | 450 | 96 | 90 | 55
Harriet Lane | 20 q8 | >34 | NA | 550 | 95 | 77 | 22
Harriet Lane | | Overall | | 1000 | 96 | 83 | 37
Neofax | 20 q12 | <37 | <34 | 441 | 97 | 89 | 55
Neofax | 20 q8 | any | >34 | 559 | 94 | 77 | 22
Neofax | | Overall | | 1000 | 95 | 82 | 37

All doses are a 1-hour infusion.

Median Cmax_ss_ for the proposed dosing regimen is predicted to overlap the range of values observed in adults and premature infants. Normalized to dosing of 20 mg/kg q8, mean peaks reported by Kimberlin were ~25 ± 7 mg/L^3^; our predicted mean peaks for this dosing are lower (12.7 ± 9.5 mg/L), and to achieve mean peaks of 25 mg/L would require dosing of 25-50 mg/kg q8 by PMA group. The range of Cmin_ss_values for the proposed dosing regimen is predicted to exceed values seen in adults, which were all ≤3 mg/L, and overlap the range of values previously observed in premature infants (Table 11-9). Greater variability in Cmax_ss_and Cmin_ss_are expected in premature infants compared with adults.

Table 11-9 Acyclovir Exposure in Different Age Groups

Reference | Population | n | IV Dosing (mg/kg) over 1 h | Daily Dose (mg/kg) | Cmax_ss_ (mg/L) | Cmin_ss_ (mg/L)
Blum 1982^7^ | Adults with normal renal function | 24 | 2.5-15 q8 | 7.5-45 | 5.1-23.6 | 0.5-2.3
Yeager 1982^6^ | Premature infants PNA <61 days | 4 | 5-15 | 15-45 | 5.1-33.7 | 0.34-23.9
Kimberlin 2001^3^ | PNA ≤28 days | 13 | 15 q8 | 45 q8 | 18.8 ± 5.22 (9.8-28.3) | 3.18 ± 2.62 (0.6-9.95)
Present study | PMA <30 weeks | 1000 | 20q12 | 40 | 11.6 (3.01-95.1) | 5.1 (1.8-19.1)
Present study | PMA 30 - <36 weeks | 1000 | 20 q8 | 60 | 9.9 (1.9-59.2) | 4.0 (1.1-12.4)
Present study | PMA 36 - 41 weeks | 1000 | 20 q6 | 80 | 9.0 (1.3-79.6) | 3.3 (0.8-9.7)

Concentrations are range, median (range), or mean ± standard deviation (range). Infusion duration not reported in Kimberlin 2001 study.

### 11.4.5 Drug-Drug and Drug-Disease Interaction

Potential drug-drug and drug-disease interactions were not investigated in this study.

### 11.4.6 By-Participant Displays

By-participant displays (i.e. “patient profiles”) are included in Figure 14.1.1. For each participant, values over the course of the study from pre-dose through 10 days from start of study drug are shown:

- Acyclovir dosing, including standard of care and study doses.
- Timed and scavenged plasma sampling.
- Concentration of acyclovir from timed and scavenged plasma samples.
- Creatinine (mg/dL) and hematocrit (%) values
- AEs

### 11.4.7 Efficacy and PK Conclusions

Surrogate PD targets of Cmax_ss_, C50_ss_, and Cmin_ss_≥3 mg/L and ≥1 mg/L were based on the HSV IC50 (1 mg/L) and reported acyclovir CNS penetration of approximately 30–50%. Based on case reports, surrogate safety targets of Cmaxss <50 and 70 mg/L were chosen to avoid potential toxicity. Using the dosing infants received in the trials, 28/28 (100%), 28/28 (100%), and 18/28 (64%) of infants had predicted Cmax_ss_, C50_ss_, and Cmin_ss_≥3 mg/L respectively; 100% of infants had predicted steady-state concentrations ≥1 mg/L throughout the dosing interval. A PMA-based dosing regimen was developed to account for developmental changes in acyclovir disposition:

- 20 mg/kg q12 hours in infants PMA <30 weeks
- 20 mg/kg q8 hours in infants PMA 30 to <36 weeks
- 20 mg/ kg q6 hours in infants PMA 36–41 weeks

Monte Carlo simulations of this dose regimen predicts Cmax_ss_, C50_ss_, and Cmin_ss_≥3 mg/L for 98%, 91%, and 71% of infants, respectively, and ≥1 mg/L for all infants throughout the dosing interval; 0.9% and 0.3% of infants exceeded the surrogate safety targets of Cmax_ss_>50 mg/L and 70 mg/L, respectively. Proposed dosing would achieve therapeutic acyclovir concentrations in the majority of infants ≤41 weeks PMA.