# 10 Study Participants

## 10.1 Disposition of Participants

A total of 32 participants were consented for the study and dosed with study acyclovir. This was originally a single center study using version 1.0 of the protocol, with 13 participants enrolled between September 2010 and February 2011. After this period, the study was included under the auspices of BPCA and re-opened as a multicenter study with different age stratification and dosing requirements. The protocol was amended to version 2.0 and two additional sites were added to the study. The target accrual was 20 evaluable participants. Evaluable participants contributed at least 3 timed fresh plasma PK samples and had a GA/PNA compatible with the groups offered in protocol version 2.0 and greater (GA 23-29 weeks/PNA <14 days, GA 23-29 weeks/PNA 14-44 days, or GA 30-34 weeks/PNA <45 days). Four participants enrolled in version 1.0 met these criteria. Enrollment into version ≥2.0 was stopped when an additional 16 evaluable version ≥2.0 participants were enrolled. During laboratory analyses after the study enrollment was closed, it was discovered that 2 fresh plasma PK samples from 2 participants were not fresh plasma. This resulted in these 2 participants being not evaluable. The final evaluable accrual was 18 participants. For this report, participants enrolled under all versions have been analyzed together. Table 10-1 presents the difference in age stratum and dosage used between protocol version 1 and protocol version ≥2.0. All participants were <45 days old at enrollment.

Table 10-1 Age Stratum and Dosage by Protocol Version

Version 1.0
GA | PNA | Dosage (for up to 5 days) | Number Enrolled
23-29 weeks | <14 days | 500 mg/m^2^ IV q8 | 1
30-42 weeks | <14 days | 500 mg/m^2^ IV q8 | 10
23-29 weeks | 14-60 days | 500 mg/m^2^ IV q8 | 1
30-42 weeks | 14-60 days | 500 mg/m^2^ IV q8 | 1
Version >2.0
GA | PNA | Dosage (for up to 3 days) | Number Enrolled
23-29 weeks | <14 days | 10 mg/kg IV q12 | 9
23-29 weeks | 14-44 days | 20 mg/kg IV q12 | 4
30-34 weeks | <45 days | 20 mg/kg IV q8 | 6

Participant accounting is summarized in Figure 10-1, Table 10-2, and in Section 14, Table 14.1.1.1. All 32 participants were administered study acyclovir and are included in the safety population. At least one fresh plasma sample was obtained from 30 of the 32 participants and are included in the PK analysis. Twenty-one (66%) of the 32 participants did not complete the study (5 days of acyclovir administration for participants enrolled under version 1.0 and 3 days of acyclovir, provide at least 3 fresh PK samples, and complete the safety follow-up for participants enrolled under versions ≥ 2.0).

Twenty one participants terminated early due to the following reasons – 10 participants terminated after a negative cultures, 4 participants were lost to follow-up (all were discharged or transferred to another facility), 2 due to AEs (worsening serum creatinine in ▬ and neuroblastoma in ▬), 2 deaths (non-ketotic hyperglycinemia in ▬ and sepsis in ▬), 2 due to investigator decision and 1 because the site knew they would not be able to obtain the minimum of 3 PK samples.

Table 10-2 Participant Disposition

Participant Accounting | GA 23-29 weeks; PNA <14 days; (n=10) | GA 23-29 weeks; PNA 14-44 days; (n=5) | GA 30-34 weeks; PNA <45 days; (n=9) | GA 35-42 weeks; PNA <14 days^*^; (n=8) | Total; (n=32)
Total Enrolled; Version 1; Version ≥2 | 10; 1; 9 | 5; 1; 4 | 9; 3; 6 | 8; 8; 0 | 32; 13; 19
Status; Completed; Early termination | 6 (60%); 4 (40%) | 4 (80%); 1 (20%) | 1 (11%); 8 (89%) | 0; 8 (100%) | 11 (34%); 21 (66%)
Reasons for early term; Negative culture; Lost to follow-up; AE; Investigator decision; Death; Insufficient sampling | 1 (10%); 0; 1 (10%); 1 (10%); 1 (10%); 0 | 0; 0; 0; 0; 0; 1 (20%) | 3 (33%); 4 (44%); 0; 1 (11%); 0; 0 | 6 (75%); 0; 1 (13%); 0; 1 (13%); 0 | 10 (31%); 4 (13%); 2 (6%); 2 (6%); 2 (6%); 1 (3%)

* The GA 35-42 weeks/PNA <14 days group was enrolled only under protocol v1.0.

Participants were enrolled at two sites in this study; see Table 14.1.1.2. ▬ enrolled 27 (84%) and ▬ enrolled 5 (16%) participants. ▬ did not enroll participants.

Figure 10-1 Flowchart – Participant Accounting

^X^ The GA 35-42 weeks/PNA <14 days group was enrolled only under protocol version1.0.

*Reasons for Early terminations include negative cultures, lost to follow-up, adverse events, deaths, due to investigator decision and insufficient sampling.

**Definition of study completion is 5 days of acyclovir administration for participants enrolled under version 1.0 and 3 days of Acyclovir, provide at least 3 fresh PK samples, and complete the safety follow- up for participants enrolled under versions ≥ 2.0.

## 10.2 Protocol Deviations

There were 32 protocol deviations reported in 23 (72%) participants for this study. In the cases of multiple identical errors, one deviation entry represented all errors for each participant. Sixteen of the 32 protocol deviations were reportedly result of hospital error and 11 (of 32) reportedly a result of research staff or clinic error. The protocol deviations are summarized in Table 14.1.3.1 and Table 14.1.3.2; the complete list of protocol deviation by participant is provided in Appendix 16.2.5. Protocol deviations are tabulated by indicated reason in Table 14.1.3.3.

Protocol deviations were associated with eligibility/enrollment (n=7), study medication administration (n=8, 7 participants with 25 total dosing errors), protocol/procedure assessments (n=15), informed consent (n=1) and other reasons (unreported AE resulting in stopping of study drug, n=1).

Five of seven participants with eligibility related protocol deviations did not have a baseline serum creatinine measured within 72 hours prior to enrollment; one participant had a baseline serum creatinine reported at 1.8 mg/dL and the other participant did not meet the weight inclusion criteria. Seven participants (8 deviations) had protocol deviations related to study medication administration (31% of all on-study doses). Four of these participants received doses that were administered out of window; one participant received doses administered over the incorrect protocol duration period; one participant had doses both out of window and of incorrect duration; and one participant remained on SOC dosing and was not increased to the protocol dose. No waivers from eligibility criteria were granted during this study.