# 9 Investigational Plan

## 9.1 Overall Design and Plan Description

The participants were divided into 3 groups based on GA and PNA. The dosage of acyclovir administered were as presented in Table 9-1.

Table 9-1 Division of Participants by Gestational Age and Postnatal Age

Group | Gestational Age | Postnatal Age | Dosage
1 | 23-29 weeks | < 14 days | 10 mg/kg IV q12
2 | 23-29 weeks | 14-44 days | 20 mg/kg IV q12
3 | 30-34 weeks | <45 days | 20 mg/kg IV q8

### 9.1.1 Study Duration

The total study duration was 9 months; each participant participated in the study for up to 13 days: 3 days of study drug administration and 10 days of safety monitoring.

## 9.2 Discussion of Study Design and Choice of Control Groups

Limited PK data on acyclovir in infants suggest that clearance is directly related to gestational and postnatal age. Therefore, acyclovir dosing in this population was expected to differ from more mature infants, older children, and adults and was expected to require specific adjustments according to those maturity factors.

## 9.3 Selection of Study Population

### 9.3.1 Inclusion Criteria

The investigator or other study site personnel documented in the source documents (e.g., the hospital chart), that informed consent was obtained. Laboratory tests or non-pharmacologic treatment procedures that were performed as standard of care within 72 hours prior to first dose of study drug were sometimes used for screening procedures and recorded in the CRF.

1. 45 days of postnatal age and < 34 weeks gestational age at the time of initial study drug administration.
2. Sufficient venous access to permit administration of study medication.
3. Availability and willingness of the parent/legal guardian to provide written informed consent.
4. Suspected HSV sepsis
  - OR
  - At least two (2) of the following
    - Signs of sepsis AND negative blood cultures for >24 hours^1^
    - Respiratory distress^2^
    - Lethargy^2^
    - Fever ≥ 38.0°C^1^
    - Skin lesions^1,2^
    - Seizures (clinical OR EEG confirmed)^1^
    - Irritability^1^
    - AST OR ALT >2 X upper limit of normal^1,2^
    - >20 WBCs/µL or >500 RBCs/µL^1^ in CSF

### 9.3.2 Exclusion Criteria

1. History of anaphylaxis attributed to acyclovir.
2. Serum creatinine >1.7 mg/dL.
3. Urine output <0.5 mL/kg/hour over the previous 12 hours
4. Previous participation in the study.
5. Concomitant condition, which in the opinion of the investigator would preclude a participant’s participation in the study.

### 9.3.3 Removal of Participants from Therapy or Assessment

If a participant in a given age group provided <3 timed plasma PK samples, a replacement participant could be enrolled for that group. All infants were included in the safety analysis and all infants with ≥1 PK sample were included in the PK analysis.

### 9.3.4 Permitted Treatment

Participants continued standard therapy for existing acute or chronic medical conditions.

## 9.4 Treatments

### 9.4.1 Treatments Administered

Each 500 mg vial of acyclovir was initially reconstituted in 10 mL of sterile water for injection to an initial concentration of 50 mg/mL. A 7 mL aliquot of this solution was then added to 43 mL of D5W to produce a final concentration of 7 mg/mL. Study drug for all participants were infused in dextrose in water over one hour. The dosage was administered every 8-12 hours for a total of 6-9 doses (3 days). The infusion was rate controlled by using appropriate infusion (syringe) pumps. In the event of an infusion reaction (histamine-mediated symptoms including rash, urticaria, flushing, facial edema, or pruritus), the infusion was halted and the participant’s condition monitored. However, no infusion-related AEs were reported. The study drug was not mixed with other drugs and a separate venous line was used if any other drugs needed to be administered simultaneously by this route.

### 9.4.2 Identity of Investigational Products

Acyclovir is a generic therapeutic and was supplied by the site pharmacy.

#### 9.4.2.1 Storage

All investigational materials were kept in a secure area inaccessible to unauthorized individuals. Acyclovir was stored at a controlled room temperature, 20-25°C (68-77°F).

### 9.4.3 Method of Assigning Participants to Treatment Groups

The participants wer e divided into 3 groups based on GA and PNA.

Table 9-2 Treatment Groups

Group | Gestational Age | Postnatal Age | Dosage
1 | 23-29 weeks | < 14 days | 10 mg/kg IV q12
2 | 23-29 weeks | 14-44 days | 20 mg/kg IV q12
3 | 30-34 weeks | <45 days | 20 mg/kg IV q8

### 9.4.4 Selection and Timing of Dose for Each Participant

#### 9.4.4.1 Selection of Doses in the Study

Prior acyclovir PK data among premature infants is extremely limited. To our knowledge, the PK of acyclovir has only been reported in 4 premature infants (youngest was 27 weeks gestation). Because of the close relationship between acyclovir clearance and renal function, dosing adjustments were expected in premature infants with different degrees of renal dysfunction according to the stage of maturation. Given this information, we anticipated a decrease in drug clearance in premature infants <35 weeks gestation, which was expected to increase with increasing postnatal age. The dosing regimen used was expected to account for these maturational changes and meet the therapeutic and safety targets of acyclovir minimum concentration (trough) at steady state ≥ 3 mg/L (3 times the IC50 against herpes simplex viruses (1 mg/L)) in 95% of participants and maximum concentrations at steady state (Cmaxss) < 50 mg/L in all participants, respectively (Appendix 16.1.1, Appendix B). The therapeutic target was chosen based on the reported CSF penetration of acyclovir (30-50%).

#### 9.4.4.2 Dosing for Infants Receiving Acyclovir per Local Standard of Care

Infants enrolled that were receiving acyclovir per local standard of care prior to study entry only had steady state PK samples obtained because 1^st^ dose levels were impossible to obtain. The infants continued to receive acyclovir at the dosing administered prior to enrollment in the study if the dose was greater than the dose indicated by this protocol for the infant’s GA/PNA. PK samples were obtained after the 5^th^ dose (groups 1 and 2) and 8^th^ dose (group 3) of acyclovir (counting both off-study and on-study doses) as long as the acyclovir doses are the same. Infants receiving acyclovir per standard of care at doses lower than doses outlined in the protocol had PK sampling their doses increased to the protocol doses. occurred after dose 5-8 of the new dosing of acyclovir depending on dosing group.

### 9.4.5 Blinding

This was an open-label study and no study treatments were blinded or masked.

### 9.4.6 Prior and Concomitant Therapy

Administration of inotropes and probenecid within 72 hours prior to the first dose of study drug through 24 hours following last dose of study drug were recorded. Administration of all acyclovir doses within 72 hours prior to the first dose of study drug were recorded.

### 9.4.7 Treatment Compliance

All participants were inpatients in the hospital. Therefore, each dose of study drug administration was given and monitored by hospital staff, then reviewed by study personnel.

## 9.5 Efficacy, Pharmacokinetic, and Safety Variables

### 9.5.1 Efficacy, Pharmacokinetic, and Safety Measurements

The study design was intended to provide the necessary data on safety, tolerance and PK of acyclovir administered to preterm and term infants. Efficacy of the drug was not determined.

#### 9.5.1.1 Safety Variables

All AEs were recorded from the time of first study drug administration through 3 days following last dose of study drug. All suspected adverse reactions, adverse reactions, and all serious events (SAEs, serious suspected adverse reactions and serious adverse reactions, defined below), were recorded from time of first study drug administration through 10 days post last study drug administration.

As all participants in this study had pre-existing medical conditions (diagnosed or undiagnosed) and were sometimes hospitalized, those pre-existing conditions were not considered as AEs. Events that were discovered based on physical examination, laboratory findings, medical chart review or other means, new events that occurred, or pre-existing conditions that worsened through frequency or intensity and met the reporting requirements described above, were reported.

Each reportable event was recorded on an AE case report form starting after study medication had been administered. The investigator provided date of onset and resolution, intensity, action(s) taken, changes in study drug dosing, causality, seriousness and outcome. AEs ongoing at the time of the last dose of study drug were followed up for up to 10 days to adequately evaluate the participant’s safety or until the event stabilizes. If the event resolved during the study or follow-up period, a resolution date was documented on the case report form.

Criteria used for assessing intensity of an AE and determining causality of an AE, follow-up of AEs, dose interruptions for SAEs, withdrawal of study medication, study termination and reporting procedures are described in the protocol (Appendix 16.1.1).

#### 9.5.1.2 Schedule of Assessments

##### 9.5.1.2.1 Baseline/Pre-Dose Assessment (Day 0/1*)

After the parent /legal guardian had signed the IRB-approved informed consent form, and after it had been determined that the participant satisfied all inclusion and exclusion criteria, the following evaluations were performed and recorded in the CRF:

1. Participant demographics.
2. Physical examination, including weight, length and urine output.
3. Laboratory and microbiologic determinations
4. At least one of the following HSV evaluations was obtained
  a. HSV surface cultures
  b. HSV blood PCR
  c. Blood viral culture
  d. HSV CSF PCR
5. Concomitant medications in the 72 hours prior to study drug administration.
6. * Day 0 was recorded if informed consent was acquired prior to the day of study drug administration. The date of Day 0 was then equaled to the informed consent date. If there was a lag between the date the informed consent was signed and the date of study drug start, pre-dose information was obtained for the period closest to the study drug start date/time and recorded in the CRF. If informed consent was acquired on the same day as study drug start, the data was recorded under Study Day 1. The date of Study Day 1 was always equal to the date of study drug start.

##### 9.5.1.2.2 Treatment Assessments (Day 1-3)

The following assessments were conducted each day while the participant is on study.

1. Study medication administration: The date and time of each dose were recorded
2. PK sampling*
3. Concomitant medications
4. Microbiologic determinations
5. AE monitoring
6. Physical exam
7. Laboratory determinations

* If receiving acyclovir as part of standard of care, only steady state PK samples were collected. See Appendix 16.1.1 (Appendix A) for PK sampling times.

##### 9.5.1.2.3 Follow-up Assessment (Day 4-13)

1. AE monitoring

##### 9.5.1.2.4 Laboratory Determinations

1. Hematology values obtained per standard of care within 72 hours prior to the first dose of study drug through 24 hours following last dose of study drug were recorded. These included: hematocrit, WBC count, platelet count, and differential. All obtained values were recorded.
2. Serum chemistry values obtained per standard of care within 72 hours prior to the first dose of study drug through 24 hours following last dose of study drug were recorded. These include: BUN, calcium, serum creatinine, potassium, sodium, AST, ALT, alkaline phosphatase, total and direct bilirubin, and albumin. All obtained values were recorded.
3. A serum creatinine was obtained within 72 hours prior to start of study drug administration to confirm eligibility criteria. The creatinine level closest to and prior to study drug start was recorded for this criteria. Additional serum creatinine levels obtained per standard of care through 24 hours after last study drug dose were recorded.

##### 9.5.1.2.5 Microbiological Determinations

Results of all blood, CSF and urine (obtained by suprapubic tap or in-and-out catheterization) cultures obtained within 72 hours of the 1st dose of study drug through 24 hours after the last dose of study drug were recorded. Infants receiving acyclovir per local standard of care sometimes did not have a culture result available.

##### 9.5.1.2.6 Concomitant Medications

Administration of inotropes and probenecid within 72 hours prior to the first dose of study drug through 24 hours following last dose of study drug were recorded. Administration of all acyclovir doses within 72 hours prior to the first dose of study drug were recorded.

##### 9.5.1.2.7 Minimizing Blood Loss

In order to minimize the amount of blood sampling, hematology and chemistry laboratory measures were obtained per local standard of care; and a limited PK sampling scheme was employed such that no more than a total of 1600 μL of blood was obtained from each participant for PK analysis. Plasma samples were collected at 200 µL blood aliquots. Every effort was made to time the plasma PK sampling with line draws or heel sticks for normal laboratory monitoring including chemistries, blood gases, and accuchecks. There were no more than 3 line draws or heel sticks specifically for PK sampling in any given infant.

### 9.5.2 Primary Efficacy Variables

This was an open label study to evaluate the plasma PK and safety of acyclovir. Efficacy of the drug was not evaluated.

### 9.5.3 Drug Concentration Measurements

Plasma samples were analyzed for acyclovir concentrations using a validated LC/MS/MS bioanalytical assay. The lower limit of quantitation was 0.01 mg/L. The calibration range was 0.1–50 mg/L. The intraday and inter-day coefficient of variation in drug concentration measurements was 14% and 8%, respectively. Assay details are reported in the assay validation report in Appendix 16.4.7.

## 9.6 Data Quality Assurance

An electronic case report form (eCRF) was used to record participant data in the Advantage EDC^SM^ system. GlobalTrace^SM^ was used as an electronic specimen inventory. The eCRF was used for the recording of all historical participant information and study data as specified by this protocol. The eCRF was completed by designated and trained study personnel. Certain data elements were collected on provided source documents, but were not entered into the Advantage EDC system. Prior to the initiation of the study, the Pediatrics Trial Network selected sites that were fully capable of carrying out the study. The BPCA DCC trained the investigators, sub-investigators and their study coordinators in eCRF completion, study management tools, and regulatory compliance. The DCRI PI trained site staff on the protocol, performance of study procedures, and specimen collection methods. In addition to the investigators’ meeting, the study personnel at each site were trained on the study procedures by a DCRI-CRA as necessary. EMMES monitored each site throughout the study. At each visit, data recorded in the EDC system were compared to source documentation to ensure accuracy. Quality assurance checks were performed to ensure that the investigators were complying with the protocol and all applicable regulations. The data for all primary outcomes were 100% monitored. In addition to the quality assurance checks incorporated into the EDC system, additional logic checks were run to check for such items such as inconsistent study dates and outlying laboratory values. Any necessary corrections were made by site staff in the eCRF and documented via audit trail, prior to study data lock.

## 9.7 Statistical Methods and Determination of Sample Size

### 9.7.1 Statistical and Analysis Plan

#### 9.7.1.1 Population to be Analyzed

All participants who received at least one dose of acyclovir. Data from participants enrolled under version 1 of this protocol at ▬ were included in the PK and safety analysis (See Section 10.1). Infants previously enrolled with ≥3 PK timed plasma PK samples and with gestational age <35 weeks were included in the total evaluable sample size for version ≥2.0 of the study.

#### 9.7.1.2 Statistical Methodology

Descriptive statistics such as number of observations, mean, median, 95% confidence interval, standard deviation, standard error, minimum, and maximum are presented for continuous variables (such as age, weight, etc.). Other descriptive statistics such as counts, proportions, and/or percentages were presented by GA and PNA group to summarize discrete variables (such as race, sex, etc.).

#### 9.7.1.3 Demographics and Baseline Characteristics

The number of participants completed, and discontinued early from study, and the reasons for discontinuation were summarized. Demographic and baseline characteristics are also summarized. Variables include race, age, sex, and selected clinical variables recorded prior to initiation of study drug. Study drug administration are summarized in terms of number of days of dosing, and reasons for final discontinuation of study drug.

#### 9.7.1.4 Safety and Clinical Laboratory Analyses

Laboratory data, such as hematology and serum chemistry data as well as safety data were analyzed by postnatal and gestational age groups. Summary statistics for changes from baseline are presented. Continuous laboratory measurements are described at each visit using univariable descriptive statistics (mean, median, etc.); observed values and changes from baseline are summarized.

#### 9.7.1.5 Pharmacokinetic Analysis

Population pharmacokinetic (PK) analysis was performed using NONMEM 7. Weight was included a priori as a significant covariate for clearance (CL) and volume of distribution (V). The following covariates were evaluated for relationships with PK parameters: serum creatinine (SCR), PNA, GA at birth, postmenstrual age (PMA), race, ethnicity, sex, and use of vasopressin, dopamine (DOPA), and epinephrine (EPI). A 2-stage approach was used to assess the impact of covariates: univariate forward inclusion followed by multivariate backwards elimination. Models were evaluated using goodness-of-fit plots, bootstrap methods, and visual predictive check (VPC). Empirical Bayesian estimates of individual participant PK parameters were generated from the final model using the post-hoc subroutine.

### 9.7.2 Determination of Sample Size

The sample size was based on the ability to describe the PK of acyclovir and to estimate the serious toxicity rate in participants. A sample size of 20 evaluable participants provided adequate precision in the PK parameter estimates (i.e. CL) that was dependent on the underlying variability of the parameter (Table 9-2). For example, assuming an inter-individual CV% of 40% in the population CL parameter estimate after weight based allometric and maturation scaling, a sample size of 20 participants would provide a margin of error of ± 18% in the 95% confidence interval of the CL estimate.

Table 9-3 Precision of PK Parameter Estimates with a Sample Size of 20 Evaluable Participants

PK Parameter CV% | 95% CI Margin of Error
40% | ± 18%
50% | ± 22%
60% | ± 26%
80% | ± 35%

The sample size provided reasonable estimates and 95% CI for safety (Table 9-3). If one infant has an adverse event, then the 95% CI (exact binomial) for that AE within the participant population of 20 participants is 0 - 25%.

Table 9-4 Estimates of Adverse Event Rates with a Sample Size of 20 Evaluable Participants

Number of Events | Proportion | 95% CI
0 | 0.00 | 0, 0.17
1 | 0.05 | 0.001, 0.25
2 | 0.10 | 0.01, 0.32
3 | 0.15 | 0.03, 0.38

## 9.8 Changes in the Conduct of the Study or the Planned Analyses

### 9.8.1 Changes in Conduct of Study

Three amendments were made to the original protocol (Version 1.0) dated October 14, 2010. The original protocol, the three amendments along with summary of changes between protocol versions are provided in Appendix 16.1.1. The amendments to the protocol are summarized below.

#### 9.8.1.1 Protocol Amendment 1

Protocol Amendment 1 (Version 2.0), dated February 4, 2011, was issued to include some major changes to the study protocol.

##### Cover page, header and footer

1. Added Duke Clinical Research Institute; Pediatric Trials Network (PTN); Sponsored by the Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD)
2. Protocol Date changed from 10/14/2010 (version 1) to “February 04, 2011 version 2”
3. Protocol title changed from “An Open Label Study to Describe the Pharmacokinetics of Acyclovir in Infants” to “An Open Label Study to Describe the Pharmacokinetics of Acyclovir in Premature Infants”

##### Protocol Synopsis

1. Changed study design from “single center” to “multi-center”
2. Changed study population from “infants ≤ 60 days postnatal age” to “infants < 45 days postnatal age”
3. Removed “Group 4: 30-42 weeks post menstrual age and 14-60 days postnatal age” from study population
4. Changed number of participants from “32” to “20”
5. Changed study drug administration duration from “5 days” to “3 days”
6. Changed number of centers from “2” to “2-5”
7. Changed duration of participant participation from “10” days to “13” days
8. Changed estimated start from “October 2009” (v1) to “March 2011”(v2)
9. Changed estimated finish from “June 30th 2010” to “September 2011”
10. Removed PK/PD and Statistical considerations from synopsis

##### List of Abbreviations

Added abbreviations – as evidenced

##### Section 1 Background

Edited – as evidenced

##### Section 2 Objective

Changed from “The primary objective is to assess the pharmacokinetics of intravenously administered acyclovir at a single center in infants less than 60 days of life with suspected infection”

To “The primary objective is to assess the PK of IV acyclovir in premature infants <35 weeks gestational age and <45 days of life.”

##### Section 3 Study Design and Rationale

Changed from “Investigational Plan of a prospective, open-label PK study of acyclovir in infants. Enrollment will continue during the interim analyses”

To “To evaluate the safety and PK of IV acyclovir in premature infants with suspected systemic infections. The participants will be divided into 3 groups based on GA and PNA.

Group | Gestational Age | Postnatal Age | Dosage
1 | 23-29 weeks | < 14 days | 10 mg/kg IV q12h
2 | 23-29 weeks | 14-44 days | 20 mg/kg IV q12h
3 | 30-34 weeks | <45 days | 20 mg/kg IV q8h

##### Section 3.1 Study Duration

Changed from “The total study duration is expected to be approximately 12 months; and each participant will participate in the study for up to 10 days”

To “The total study duration is expected to be approximately 6 months; and each participant will participate in the study for up to 13 days: 3 days of study drug administration and 10 days of safety monitoring.”

##### Section 3.2 Rationale for Study Design

Added “Although acyclovir is widely used in this population, limited PK data for acyclovir exist.”

##### Section 3.3 Inclusion Criteria

1. Changed from “Infant <4500g and ≤ 60 days old at the time of initial study drug administration” To “< 45 days of age at the time of initial study drug administration”
2. Changed from “Infant suspected to have systemic infection and appropriate cultures (blood +/-urine/CSF) are obtained within 48 hours of study entry. Urine and CSF cultures will be obtained based on clinical index of suspicion, but are not required for enrollment; or receiving Acyclovir as part of standard of care” To “Suspected HSV sepsis OR two (2) of the following:
3. Signs of sepsis AND negative blood cultures for >24 hours
4. Respiratory distress
5. Lethargy
6. Fever ≥ 38.0°C
7. Skin lesions
8. Seizures (clinical OR EEG confirmed)
9. Irritability
10. AST OR ALT >2 X upper limit of normal
11. >20 WBCs/µL or >500 RBCs/µL”

##### Section 3.4 Exclusion Criteria

Changed from:

1. Participants with a history of anaphylaxis attributed to acyclovir.
2. Renal dysfunction indicated by serum creatinine >1.7 mg/dL
3. Previous participation in the study.
4. Any other concomitant condition, which in the opinion of the investigator would preclude a participant’s participation in the study.
5. Infants >4500g and >60days old at time of initial study drug administration.

To:

1. History of anaphylaxis attributed to acyclovir.
2. Serum creatinine >1.7 mg/dL.
3. Urine output <0.5 mL/kg/hour over the previous 12 hours
4. Previous participation in the study.
5. Concomitant condition, which in the opinion of the investigator would preclude a participant’s participation in the study.

##### Section 3.5 Replacement Participants

Changed from “If a participant in a given age cohort receives < 3 PK samples, a replacement participant may be entered for that age cohort”

To “If a participant in a given age group provides <3 timed plasma PK samples, a replacement participant may be entered for that group. All infants will be included in the safety analysis and all infants with ≥1 PK sample will be included in the PK analysis.”

###### Methods and Dosage and Administration

Sections removed from the protocol text and addressed in the Appendices.

##### Section 3.6 Permitted Treatment

Changed from “Participants may continue standard therapy for existing acute or chronic medical conditions. A participant who develops a viral infection (superficial or invasive) may be treated with an additional antiviral medicine in accordance with the local standard of care. All participants will receive study drug in addition to other antibiotics and antivirals being administered as part of the standard of care.”

To “Participants may continue standard therapy for existing acute or chronic medical conditions.”

##### Section 4.1 Rationale for Dose Selection

Paragraph was added to protocol

##### Section 4.2 Drug Supplies

a. Section name changed from “Study Medication” to “Drug Supplies”
b. Changed from “Administration of acyclovir will be initiated after criteria for entry into the study are met. Study drug for all participants will be infused in dextrose in water over one hour. The study drug will be mixed to a final concentration of 5 mg/mL. The dosage should be administered every 8 hours. The final acyclovir concentration in solution will be 5 mg/ml. An in-line filter is unnecessary. The infusion must be rate controlled by using appropriate infusion (syringe) pumps. Acyclovir is manufactured by Bedford Laboratories. Acyclovir is packaged in a glass vial. Each vial contains 500 mg of lyophilized acyclovir”
  To “Acyclovir is a generic therapeutic and will be supplied by the site pharmacy. “

##### Section 4.3 Storage/Reconstitution/Dilution/Administration

Changed from “All investigational materials should be kept in a secure area inaccessible to unauthorized individuals. Acyclovir should be stored at a controlled room temperature, 20-25ºC (68-77ºF). Each 500 mg vial of acyclovir is initially reconstituted in 10 mL of sterile water for injection to an initial concentration of 50 mg/mL. A 5 mL aliquot of this solution is then added to 45 mL of D5W to produce a final concentration of 5 mg/mL”

To “All investigational materials must be kept in a secure area inaccessible to unauthorized individuals. Acyclovir should be stored at a controlled room temperature, 20-25ºC (68-77ºF). Each 500 mg vial of acyclovir is initially reconstituted in 10 mL of sterile water for injection to an initial concentration of 50 mg/mL. A 5 mL aliquot of this solution is then added to 45 mL of D5W to produce a final concentration of 5 mg/mL. Study drug for all participants will be infused in dextrose in water over one hour. The dosage will be administered every 8-12 hours for a total of 6-9 doses (3 days). An in-line filter is unnecessary. The infusion must be rate controlled by using appropriate infusion (syringe) pumps. In the event of an infusion reaction (histamine-mediated symptoms including rash, urticaria, flushing, facial edema, or pruritus), the infusion should be halted and the participant’s condition monitored. Rarely is medical treatment required other than temporary cessation of the infusion. After resolution of symptoms the infusion should be resumed at the same rate. The study drug should not be mixed with other drugs and a separate venous line should be used if any other drugs need to be administered simultaneously by this route.”

##### Section 4.4 Dosing for Infants Receiving Acyclovir per Local Standard of Care

Added section

##### Section 5.1 Baseline/Pre-Dose Assessment (Day 0/1*)

1. Added “length and urine output”
2. Added “At least one of the following HSV evaluations must be obtained: HSV surface cultures; HSV blood PCR; Blood viral culture; HSV CSF PCR”
3. Clarifying text was added “*Day 0 is recorded if informed consent is acquired prior to the day of study drug administration. The date of Day 0 is then equal to the informed consent date. If there is a lag between the date the informed consent is signed and the date of study drug start, pre-dose information should be obtained for the period closest to the study drug start date/time and recorded in the CRF. If informed consent is acquired on the same day as study drug start, the data are recorded under Study Day 1. The date of Study Day 1 is always equal to the date of study drug start.”

##### Section 5.2 Treatment Assessments (Day 1-3)

1. Changed section header from “Treatment Assessments (Day 1-5)” to Treatment Assessments (Day 1-3)
2. Added “Adverse event monitoring, Physical exam, Laboratory determinations and Microbiologic determinations”
3. PK sampling times moved from this section to Appendix A.

##### Section 5.3 Follow-up Assessment (Day 4-13)

Changed from “For 72 hours following the last dose of acyclovir the infant will be followed for the development of adverse events and 7 days for the development of serious adverse events. These will be recorded on the CRF”

To “Adverse event monitoring”.

##### Section 5.4 Laboratory Determinations

Added “A serum creatinine must be obtained within 72 hours prior to start of study drug administration to confirm eligibility criteria. The creatinine level closest to and prior to study drug start should be recorded for this criteria. Additional serum creatinine levels obtained per standard of care through 24 hours after last study drug dose will be recorded.”

##### Section 5.5 Microbiological Determinations

Changed from “Blood cultures (within 48 hours before study entry): At least one (1) aerobic blood culture will be obtained for lysis centrifugation using the BacTAlert or BacTec methods. If CSF or urine (obtained by catheterization or suprapubic tap) is collected as part of the sepsis work-up, these results should be recorded on the CRF. Surface Cultures (within 48 hours of study entry): one surface swab of eyes, mouth, skin lesions, and rectum. CSF (if indicated per clinical care): HSV PCR of CSF”

To “Results of all blood, CSF and urine (obtained by suprapubic tap or in-and-out catheterization) cultures obtained within 72 hours of the 1st dose of study drug through 24 hours after the last dose of study drug will be recorded. Infants receiving acyclovir per local standard of care may not have a culture result available.”

##### Section 5.6 Concomitant Medications

Added “Administration of inotropes and probenecid within 72 hours prior to the first dose of study drug through 24 hours following last dose of study drug should be recorded. Administration of all acyclovir doses within 72 hours prior to the first dose of study drug will be recorded.”

##### Section 5.7 Minimizing Blood Loss

Changed from “In order to minimize the amount of blood sampling, hematology and chemistry laboratory measures will be obtained per local standard of care; and a limited pharmacokinetic sampling scheme will be employed such that no more than a total of 1.4 mL of blood is obtained from each participant for pharmacokinetic analysis. Blood samples will be collected in 100-200 µL aliquots. Infants who have only 1 evaluable sample will be included in the analysis, but additional subjects may be enrolled to ensure at least 6 infants with 3 adequate samples per cohort. Every effort will be made to time the PK sampling with line draws or heel sticks for normal laboratory monitoring including chemistries, blood gases, and accuchecks. This should result in 0 or 1 additional line draw or heel stick specifically for PK sampling in any given infant”

To “In order to minimize the amount of blood sampling, hematology and chemistry laboratory measures will be obtained per local standard of care; and a limited PK sampling scheme will be employed such that no more than a total of 1600 μL of blood is obtained from each participant for PK analysis. Plasma samples will be collected at 200 µL blood aliquots. Every effort will be made to time the plasma PK sampling with line draws or heel sticks for normal laboratory monitoring including chemistries, blood gases, and accuchecks. There will be no more than 3 line draws or heel sticks specifically for PK sampling in any given infant.”

##### Section 6 Definitions and Detailed Descriptions of Assessments/Endpoints

Changed from “PHARMACOKINETIC SAMPLE HANDLING PROCEDURES: The sample will be collected at the specified time ideally at the same time as a blood draw for standard clinical practice indications. The samples will then be spun at 4ºC at 2400 rpm for 10 minutes within 30 minutes of collection. The spun sample will then be stored at -20ºC. Samples will then be stored until all samples have been collected at which time they will be sent as a single shipment to the Analytical Chemistry Laboratory at the University of North Carolina at Chapel Hill”

To “Endpoints This is an open label study to evaluate the plasma PK and safety of acyclovir.

- PK Endpoints
- Area under the curve at steady state (AUCss)
- Maximum concentration (Cmax)
- Minimum concentration at steady state (Cminss)
- Clearance (CL)
- Volume of distribution at steady state (Vss)”

##### Section 7 Safety Risks

1. Changed from “Guidelines for Assessing Intensity and Causality of an Adverse Event” To Guidelines for assessing “Serious Events (Serious Adverse Events, Serious Suspected Adverse Reactions or Serious Adverse Reactions) and Unexpected Adverse Events”.
2. Added “Section 7.5 Identification of Events and Timeframe for Reporting”.

##### Section 7.6 Guidelines for Assessing Intensity of an Adverse Event

Deleted “LIFE THREATENING: Subject is at immediate risk of death from the reaction as it occurred”

##### Section 7.7 Guidelines for Determining Causality of an Adverse Event

Changed from:

- “NOT RELATED: an event, illness or effect of another drug not related to the trial medication (e.g., has no temporal relationship to trial drug or has a definite alternative etiology)
- UNLIKELY: an adverse event not commonly associated with the drug class; has little or no temporal relationship to trial medication; and an alternative etiology is likely
- POSSIBLY RELATED: an adverse event not commonly associated with the drug class; has little or no temporal relationship to trial medication; and a probable alternative etiology is apparent
- PROBABLY RELATED: an adverse event not commonly associated with this drug class; has a temporal relationship to trial medication; and a possible alternative etiology exists or no alternative etiology is apparent
- DEFINITELY RELATED: an adverse event commonly associated with this drug class; has a temporal relationship to trial medication and/or reappeared on re-challenge; and no other etiology is apparent”

To: “The Investigator will use the following question when assessing causality of an adverse event to study drug: Is there a reasonable possibility that the drug caused the event? An affirmative answer designates the event as a suspected adverse reaction.”

##### Section 7.8 Follow up of Adverse Events

Added “Reportable events that are identified at the last assessment (or the early termination visit) must be recorded on the AE CRF with the status of the AE noted and followed until resolution. All serious suspected adverse reactions will be followed until resolution. All other events that cannot be resolved at the last study contact will be considered resolved by convention and entered in the EDC as such. Any event beginning more than 10 days after the last dose of study drug will not be captured.”

##### Section 7.9 Dose Interruptions for SAEs

Added “If the participant experiences a serious suspected adverse reaction, the study drug will be held until the reaction abates or stabilizes.”

##### Section 7.10 Withdrawal of Study Medication

1. Changed from “Participant develops an unacceptable adverse event thought to be related to IV study drug” To “Participant develops a serious adverse reaction i.e. an acute anaphylactic reaction to the study drug.”
2. Added “Known serum creatinine >1.7 mg/dL.

##### Section 7.11 Study Termination

Added “The study enrollment and dosing will be halted for a safety review if serious suspected adverse reactions or adverse reactions occur in ≥50% of participants at any time after the first 6 participants are enrolled in the study. This information will be submitted to the BPCA data monitoring committee (DMC), NICHD, and FDA along with an analysis and future plans for the study.”

##### Section 7.12 Reporting Procedures

Added “All reportable adverse events will be entered into the data system within 7 days of identification. All serious events will be entered into the data system within 24 hours of identification. Any serious event entered into the EDC will generate automatic email notification to the DCC, BPCA medical monitor and the sponsor. The BPCA medical monitor will review all SAEs at the time they are reported. Investigators must submit safety reports as required by their Institutional Review Board (IRB) independent of the reporting requirements specified in the protocol. Any event that requires expedited reporting based on federal regulations will be forwarded to the IND sponsor. The sponsor or its representative will submit expedited safety reports (IND Safety Reports) to the FDA and other regulatory agencies as necessary, and will inform the investigators of such regulatory reports. Investigators must submit IND safety reports as required by their Institutional Review Board (IRB). Documentation of the submission to and receipt by the IRB should be retained for each IND safety report.”

##### Section 8.1 Sample Size

Changed from: “The sample size is based on the ability to describe the pharmacokinetics of acyclovir. The study is also designed to provide safety information and preliminary efficacy information that can be used to design future acyclovir studies in children” to “The sample size is based on the ability to describe the PK of acyclovir and to estimate the serious toxicity rate in participants.”

To: “A sample size of 20 participants will provide adequate precision in the PK parameter estimates (i.e., CL) that will be dependent on the underlying variability of the parameter (see table below). For example, assuming an inter-individual CV% of 40% in the population CL parameter estimate after weight based allometric and maturation scaling, a sample size of 20 participants would provide a margin of error of ± 18% in the 95% confidence interval of the CL estimate.

PK Parameter CV% | 95% CI Margin of Error
40% | ± 18%
50% | ± 22%
60% | ± 26%
80% | ± 35%

Nine participants were enrolled in Group 3 with the goal to link the final PK data with published PK data obtained from term infants.

The sample size will provide reasonable estimates and 95% CI for safety (see table below). If one infant has an adverse event, then the 95% CI (exact binomial) for that AE within the participant population of 20 participants is 0 - 25%.”

Number of Events | Proportion | 95% CI
0 | 0.00 | 0, 0.17
1 | 0.05 | 0.001, 0.25
2 | 0.10 | 0.01, 0.32
3 | 0.15 | 0.03, 0.38

##### Section 8.2 Population to be Analyzed

Added “All participants who receive at least one dose of acyclovir. Data from participants enrolled under version 1 of this protocol at ▬ (IND#106153) will be included in the PK and safety analysis. Infants previously enrolled with ≥3 PK timed plasma PK samples will be included in the total sample size for this version (2.0) of the study.”

##### Section 8.3 Statistical Methodology

Statistical Analysis section broken out into Section 8.3 Statistical Methodology, Section 8.4 Demographics and Baseline Characteristics, Section 8.5 Safety, Clinical Laboratory Analyses and Section 8.6 Pharmacokinetic Analysis.

##### Section 9 Termination of Study

Section added

##### Section 10 Administrative Aspects

1. Text under “Institutional Review Board” deleted.
2. Text under “Independent Ethics Committee” deleted.
3. Header changed from “Amendments and/or Changes to Informed Consent/Authorization” to “Section 10.2 Signed Informed Consent/Authorization”

##### Section 10.3 Duties of the Investigator

Changed from “The investigator is obligated to conduct this study in accordance with U.S. federal regulation 21 CFR 312.60-69 as specified on the signed form FDA 1572, applicable state laws, and the International Conference on Harmonization: Good Clinical Practice: Consolidation Guideline. The investigator is responsible for informing the IRB of any safety issues related to the study and the study drug including reports of serious adverse events.”

To “The investigator is obligated to conduct this study in accordance with U.S. federal regulation 21 CFR 312.60-69 as specified on the signed form FDA 1572, applicable state laws, and the International Conference on Harmonization: Good Clinical Practice: Consolidation Guideline. The investigator is responsible for informing the IRB of any safety issues related to the study and the study drug including reports of serious adverse events, if required, and all IND safety reports. It is the investigator’s responsibility to retain all records and documents (including electronic data capture materials) pertaining to the conduct of the study and the distribution of the investigational drug for two years following market approval for intended application or discontinuation of study. It is recommended, however, that records be retained for at least 5 years in the event follow-up is necessary to help determine any potential hazards to participants who took part in these studies. For Pediatric studies such as this, study data is retained until participants are 21 years old. Data generated by the methods described in the protocol will be recorded in the participant’s medical records and/or study progress notes. Data may be transcribed on electronic case report forms supplied for each participant or directly inputted into an electronic system or any combination thereof. The investigator will agree to provide access to the office, clinic, and/or hospital records of all participants entered in this study. All records may be subject to inspection by officials of the FDA or other health authorities. The Principal Investigator (PI) is responsible for keeping the IRB advised of the progress of the study and of any changes made to the protocol as deemed appropriate throughout the study and not to exceed one year. The PI is also responsible for notifying the IRB of any reportable adverse events that occur during the study. The original signed informed consent form for each participant shall be filed with records kept by the Investigator. A copy of the informed consent document must be provided to the participant’s or legal authorized representative.”

##### Section 10.4 Records of the Study

Changed from “It is the investigator’s responsibility to retain all records and documents (including electronic data capture materials) pertaining to the conduct of the study and the distribution of the investigational drug for two years. It is recommended, however, that records be retained for at least 5 years in the event follow-up is necessary to help determine any potential hazards to participants who took part in these studies. For Pediatric studies such as this, study data is retained until subjects are 21 years old. Data generated by the methods described in the protocol will be recorded in the participant’s medical records and/or study progress notes. Data may be transcribed on electronic case report forms supplied for each participant or directly inputted into an electronic system or any combination thereof. The investigator will agree to provide access to the office, clinic, and/or hospital records of all participants entered in this study. All records may be subject to inspection by officials of the FDA or other health authorities. The investigator shall make accurate and adequate written progress reports to the IRB at appropriate intervals, not exceeding one year. The investigator shall make an accurate and adequate final report to the IRB within three months after completion or termination of the study.”

To “An electronic case report form (eCRF) will be used to record all participant data. The CRF will be used for the recording of all historical participant information and study data as specified by this protocol. The eCRF must be completed by designated and trained study personnel. Source documents are defined as the results of original observations and activities of a clinical investigation. Source documents may include, but are not limited to, study progress notes, e-mail correspondences, computer printouts, laboratory data and recorded data from automated instruments. All source documentation must be signed by the individual who collected the information, and certain source material (e.g., eligibility criteria review, medical history review, adverse events documentation, and laboratory result interpretation) must be reviewed and signed by a licensed clinician identified on the Form FDA 1572.”

##### Section 10.5 Regulatory Requirements

- Added

##### Section 10.6 Participant Privacy/Authorization

- Added

##### Section 11.1 Appendix A: PK Sampling

- Added

##### Section 11.2 Appendix B: Clinical Pharmacology Plan

- Added

##### References

- Modified – as evidenced

#### 9.8.1.2 Protocol Amendment 2

Protocol Amendment 2 (Version 3.0) dated June 9, 2011, was issued to clarify the intent of some sections of the Version 2.0 of the protocol and make minor changes to study design.

##### Cover page, header and footer

1. Protocol Date changed from “February 04, 2011” to “June 9, 2011”
2. Protocol Version changed from “Version 2.0” to “Version 3.0”

##### Section 3.3 Inclusion Criteria

Changed from: “Suspected HSV sepsis OR Two (2) of the following” To: “Suspected HSV sepsis OR At least two (2) of the following”

##### Section 4.3 Storage/Reconstitution/Dilution/Administration

1. Changed from “…… A 5 mL aliquot of this solution is then added to 45 mL of D5W to produce a final concentration of 5 mg/mL” to “……A 7 mL aliquot of this solution is then added to 43 mL of D5W to produce a final concentration of 7 mg/mL”.
  Rationale of change: to be in compliance with the ISMP/VONN recommendations that were released recently (http://www.ismp.org/tools/PediatricConcentrations.pdf)

##### Section 7.5 Identification of Events and Timeframe for Reporting

1. Changed from “…The investigator will provide date of onset and resolution, intensity, action(s) taken, changes in study drug dosing, causality, frequency and outcome.” to “…. The investigator will provide date of onset and resolution, intensity, action(s) taken, changes in study drug dosing, causality, seriousness and outcome.”
  Rationale of change: Frequency of the AE is not collected on the CRF for this study, hence it is deleted. Seriousness (SAE criteria) along with severity and relationship assessment is required by the investigator. This was inadvertently missed on the previous version.

##### Section 7.8 Follow-up of Adverse Events

Changed from “…All other events that cannot be resolved at the last study contact will be considered resolved by convention and entered in the EDC as such.” to “…. All other events that cannot be resolved by 30 days post last study contact will be considered resolved by convention and entered in the EDC as such.”

Rationale of change: Resolved by convention is an option in EMMES EDC to close ongoing AEs. It is a protocol clarification as to when this option can be exercised.

##### ICF Template Summary of Changes from 2011.02.04 to 2011.06.09

Changed signature lines from “Date” to “Date / Time” to capture time of consent

#### 9.8.1.3 Protocol Amendment 3.0

Protocol Amendment 3 (Version 4.0) dated March 30, 2012, was issued to clarify the intent of some sections of the Version 3.0 of the protocol and make minor changes to study design.

##### Cover page, header and footer

1. Protocol Date changed from “June 9, 2011” to “March 30, 2012”
2. Protocol Version changed from “Version 3.0” to “Version 4.0”

##### Protocol Synopsis

1. The following text to Number of Participants: Approximately 20 evaluable participants. Evaluable is defined as participants with ≥3 fresh plasma PK samples.
  Rationale: To enable study to enroll 20 participants with at least 3 fresh plasma PK samples.
2. Changed “Estimated Start of March 2011” to “Start September 2011”.
  Rationale: First participant enrolled in September 2011.
3. Changed Estimated finish from September 2011 to June 2012
  Rationale: Study still enrolling.

##### Section 3 Study Design and Rationale

Removed column with numbers of participants per age group

Rationale: Due to difficulty enrolling subjects into Group 2 (GA 23-29 weeks; PNA 14-44 days), we will enroll additional infants into Cohorts 1 and 3 to obtain 20 evaluable study participants.

##### Section 3.1 Study Duration

Text changed from “6 months” to “9 months”

Rationale: Study still enrolling.

##### Section 3.3 Inclusion Criteria

Text changed from: “<45 days at the time of initial study drug administration” to “<45 days of postnatal age and <34 weeks gestational age at the time of initial study drug administration.”

Rationale: Missed <34 weeks gestational age in inclusion criteria previously, but was oldest gestational age to be studied in protocol.

##### Section 8.1 Sample Size

1. The following text was added: “A sample size of 20 evaluable participants…”
  Rationale: To enable study to enroll 20 participants with at least 3 fresh plasma PK samples.
2. Text changed from: “Only 4 participants will be enrolled in Group 3 with the goal to link the final PK data with published PK data obtained from term infants” to “Approximately 4 participants will be enrolled in Group 3 with the goal to link the final PK data with published PK data obtained from term infants.”
  Rationale: Due to difficulty enrolling subjects into Group 2 (GA 23-29 weeks; PNA 14-44 days), we will enroll additional infants into Cohorts 1 and 3 obtain 20 evaluable study participants.

##### Section 8.2 Population to be Analyzed

The following text was removed: “Infants previously enrolled with ≥3 PK timed plasma PK samples will be included in the total sample size for this version (2.0) of the study.”

Rationale: This is now Version 4.0 of the protocol.

##### Section 11.1 Appendix A: PK Sampling

1. Text changed from: “Last dose: 6-7 hours after the last dose (Groups 1 and 2) and 10-11 hours after the last dose (Group 3)” to “Last dose:15-18 hours after drug administration” Rationale: Typographical error
2. Added text, “when possible” to PK draw windows to illustrate that samples drawn out of protocol defined windows are not protocol deviations.

##### Section 11.2 Appendix B: Clinical Pharmacology Plan

Sample Size

1. The following text was added: “The sample size is based on the ability to observe a serious toxicity rate and to describe the PK of acyclovir. A sample size of 20 evaluable subjects will provide adequate precision in the PK parameter estimates (i.e., CL) that will be dependent on the underlying variability of the parameter (see table below). For example, assuming an inter-individual CV% of 40% in the population CL parameter estimate after weight based allometric and maturation scaling, a sample size of 20 evaluable subjects would provide a margin of error of ±18% in the 95% confidence interval of the CL estimate.”
  Rationale: To enable study to enroll 20 participants with at least 3 fresh plasma PK samples.
2. Text changed from: “Only 4 participants will be enrolled in Group 3 with the goal to link the final PK data with published PK data obtained from term infants” to “Approximately 4 participants will be enrolled in Group 3 with the goal to link the final PK data with published PK data obtained from term infants.”
  Rationale: Due to difficulty enrolling subjects into Group 2 (GA 23-29 weeks; PNA 14-44 days), we wil l enroll additional infants into Cohort 1s and 3 obtain 20 evaluable study participants.

### 9.8.2 Changes in Planned Analyses

Changes to the analyses after finalization of the Statistical Analysis Plan included:

- Table 14.1.1.3 (Selected Inclusion and Exclusion Criteria) is presented by protocol version instead of by GA/PNA group.
- Table 14.4.1 (Summary of Study Doses) is presented by protocol dosing group instead of by GA/PNA group.
- Table 14.4.3 (Summary of PK Concentration Results) is presented by protocol dosing group instead of by GA/PNA group.
- Table 14.4.4.1 has been renamed to 14.4.4 (Summary of PK Concentration Results for Timed Fresh Plasma Samples by PK Sampling Windows) and is presented by protocol version instead of by GA/PNA group.
- Table 14.4.4.2 is not included because there were no scavenged samples collected during the PK sampling windows.