# 8 Study Objectives

The primary objective of this study was to assess the PK of IV acyclovir in term and preterm infants.