# 7 Introduction

## 7.1 Neonatal HSV Infection

Neonatal herpes infection carries a major risk of death if untreated. Prognosis is related to disease extent and timing of therapy, making early diagnosis crucial. Mortality in the preantiviral era was 90% for disseminated disease and 50% for central nervous system (CNS) disease. Institution of high-dose (60 mg/kg/day) antiviral therapy with acyclovir has reduced mortality to 31% for disseminated disease and 6% for CNS disease.^3^ Although acyclovir has reduced mortality dramatically, morbidity remains high.

## 7.2 Acyclovir Background

Acyclovir is a nucleoside analog of guanine, that lacks a 3’ hydroxyl group on its side chain. The drug is phosphorylated to acyclo-GMP by the viral thymidine kinase 3000 fold more efficiently than cellular thymidine kinase. The phosphorylated drug is then incorporated into a nascent DNA sequence by DNA polymerase which terminates replication. Acyclo-GTP has 100 times higher affinity for viral DNA polymerase than cellular DNA polymerase.

## 7.3 Pediatric Pharmacokinetics

### 7.3.1 Distribution

The PK disposition of acyclovir was described as a two-compartment model.^4,5^ Acyclovir levels in CSF are approximately 30-50 percent of corresponding plasma levels.^6^ Plasma protein binding is low ~15% and drug interactions involving binding displacement is not expected.^7,8^ In adults, the volume of distribution at steady state is about two-thirds of the body weight.^8^

### 7.3.2 Elimination

Acyclovir is primarily excreted renally through a combination of glomerular filtration and tubular secretion. Thus clearance and half-life are dependent on renal function.^8^ In the infant a statistically significant relationship was demonstrated between clearance and serum creatinine. The average half-life (t_1/2_) of acyclovir in infants with serum creatinine level <1 mg/dl (88 µmol/L) was 5.0 hours, and 15.6 hours for those with serum creatinine level >1 mg/dl.^5^ In another series, the mean half-life (t_1/2_beta) of acyclovir was 3.8 +/- 1.2 hours. The t_1/2_of its beta phase of elimination was three hours with normal renal function and increased to 18 hours with anuria.^8^ The mean percent urinary recovery of acyclovir at each dosage level was similar, with an overall mean recovery of 65 percent. The mean acyclovir concentration in urine did not exceed the solubility of acyclovir in bladder urine (1300 µg/ml). Generally, neonatal acyclovir PK in full term neonates was consistent with previous reports from studies of adults.^4^

### 7.3.3 Dosing

Dose-independent PK is observed in the range of 0.5 to 15 mg/kg/dose.^7,8^ Proportionality between dose and plasma levels is seen after single doses or at steady state after multiple dosing. Similar plasma levels are achieved in adults and pediatric participants (>1 year) when equivalent oral doses are given based on body surface area.^7^ Mean peak acyclovir levels in infants (mg/L +/- standard deviation) at 5, 10, and 15 mg/kg IV per dose were 6.75 +/- 2.23, 13.8 +/- 4.12, and 19.4 +/- 5.29 with corresponding mean trough levels (mg/L +/- standard deviation) of 1.19 +/- 0.77, 2.27 +/- 1.89, and 3.11 +/- 2.50, respectively.^4^

### 7.3.4 Dosing in Term and Preterm Infants

Acyclovir was administered to nine term and preterm infants IV in a dosage of 5 to 15 mg/kg every eight hours for five to 10 days. The peak serum acyclovir levels ranged from 4.5–36.7 mg/L, and the trough levels ranged from 0.225–29.0 mg/L. There was wide variation in the serum levels obtained for infants receiving the same dose, but correlated with the expected renal maturity of the individual infant.^6^