# 6 Investigators and Study Administrative Structure

## 6.1 Principal Investigators

The study was initiated at 3 sites in the United States. A list of investigators is provided in Appendix 16.1.4.

## 6.2 Administrative Structure

The following is a list of organizations that were critical to the conduct of the study:

IND SPONSOR | P. Brian Smith, MD, MPH, MHS
IND SPONSOR | Professor of Pediatrics
IND SPONSOR | Duke Clinical Research Institute (DCRI)
IND SPONSOR | 2400 Pratt St.
IND SPONSOR | Durham, NC 27715
PRINCIPAL INVESTIGATORS | P. Brian Smith, MD, MPH, MHS
PRINCIPAL INVESTIGATORS | Professor of Pediatrics
PRINCIPAL INVESTIGATORS | Duke Clinical Research Institute
PRINCIPAL INVESTIGATORS | 2400 Pratt St.
PRINCIPAL INVESTIGATORS | Durham, NC 27715
PRINCIPAL INVESTIGATORS | ▬
PRINCIPAL INVESTIGATORS | Danny Benjamin, MD, MPH, PhD
PRINCIPAL INVESTIGATORS | Kiser-Arena Distinguished Professor
PRINCIPAL INVESTIGATORS | Duke Clinical Research Institute
PRINCIPAL INVESTIGATORS | 2400 Pratt St.
PRINCIPAL INVESTIGATORS | Durham, NC 27715
PRINCIPAL INVESTIGATORS | ▬
FUNDING SPONSOR | David Siegel, MD
FUNDING SPONSOR | Eunice Kennedy Shriver National Institute of Child Health and Human Development, National Institutes of Health (NICHD)
FUNDING SPONSOR | 6710B Rockledge Drive ▬
FUNDING SPONSOR | ▬
BPCA DCC / CONTRACT RESEARCH ORGANIZATION; Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | The Emmes Corporation
BPCA DCC / CONTRACT RESEARCH ORGANIZATION; Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | 401 N. Washington Street, Suite 700
BPCA DCC / CONTRACT RESEARCH ORGANIZATION; Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | Rockville MD 20850
BPCA DCC / CONTRACT RESEARCH ORGANIZATION; Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | ▬
BPCA DCC / CONTRACT RESEARCH ORGANIZATION; Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | PI:▬
BPCA DCC / CONTRACT RESEARCH ORGANIZATION; Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | Project Director: ▬
MEDICAL MONITOR | ▬, MD
MEDICAL MONITOR | Chief Medical Officer
MEDICAL MONITOR | The Emmes Corporation
MEDICAL MONITOR | 401 N. Washington Street, Suite 700
MEDICAL MONITOR | Rockville, MD 20850
MEDICAL MONITOR | ▬
DRUG CONCENTRATION DETERMINATION | ▬, BScPhm, PharmD, DABCP
DRUG CONCENTRATION DETERMINATION | ▬
DRUG CONCENTRATION DETERMINATION | Division of Pharmacotherapy and Experimental Therapeutics, Eshelman School of Pharmacy
DRUG CONCENTRATION DETERMINATION | Director, UNC Center for AIDS Research Clinical Pharmacology and Analytical Chemistry Core
DRUG CONCENTRATION DETERMINATION | ▬
DRUG CONCENTRATION DETERMINATION | University of North Carolina at Chapel Hill
DRUG CONCENTRATION DETERMINATION | Chapel Hill, NC 27599-7569
PHARMACOKINETIC ANALYSIS | ▬, PharmD
PHARMACOKINETIC ANALYSIS | Duke Clinical Research Institute
PHARMACOKINETIC ANALYSIS | 2400 Pratt Street
PHARMACOKINETIC ANALYSIS | Durham, NC 27715
PHARMACOKINETIC ANALYSIS | ▬, MD, PhD
PHARMACOKINETIC ANALYSIS | Duke Clinical Research Institute
PHARMACOKINETIC ANALYSIS | 2400 Pratt Street
PHARMACOKINETIC ANALYSIS | Durham, NC 27715
PHARMACOKINETIC ANALYSIS | ▬, PharmD
PHARMACOKINETIC ANALYSIS | University of California San Diego
PHARMACOKINETIC ANALYSIS | 9500 Gilman Drive, ▬ 1
PHARMACOKINETIC ANALYSIS | La Jolla, CA 92093-0831