# 15 Reference List

1 Pickering LK. Red Book. 28th ed. Elk Grove Village, Illinois: American Academy of Pediatrics; 2008.
2 Kimberlin DW. When should you initiate acyclovir therapy in a neonate? J Pediatr. 2008; 153(2):155–156.18639724
3 Kimberlin DW, Lin CY, Jacobs RF, . Safety and efficacy of high-dose intravenous acyclovir in the management of neonatal herpes simplex virus infections. Pediatrics. 2001;108(2):230–238.11483782
4 Hintz M, Connor JD, Spector SA, Blum MR, Keeney RE, Yeager AS. Neonatal acyclovir pharmacokinetics in patients with herpes virus infections. Am J Med. 1982;73(1A):210–214.6285713
5 Englund JA, Fletcher CV, Balfour HH, Jr. Acyclovir therapy in neonates. J Pediatr. 1991;119(1 Pt 1):129–135.2066845
6 Yeager AS. Use of acyclovir in premature and term neonates. Am J Med. 1982;73(1A):205–209.
7 Blum MR, Liao SH, de Miranda P. Overview of acyclovir pharmacokinetic disposition in adults and children. Am J Med. 1982;73:186–192.7048911
8 Lietman PS. Acyclovir clinical pharmacology. An overview. Am J Med. 1982;73(1A):193–196.7048912
9 Rabalais GP, Nusinoff-Lehrman S, Arvin AM, Levin MJ. Antiviral susceptibilities of herpes simplex virus isolates from infants with recurrent mucocutaneous lesions after neonatal infection. Pediatr Infect Dis J. 1989;8(4):221–223.2541398
10 Wade JC, Hintz M, McGuffin R, Springmeyer SC, Connor JD, Meyers JD. Treatment of cytomegalovirus pneumonia with high-dose acyclovir. Am J Med. 1982;73(1A):249–256.6285716
11 Wade JC, Meyers JD. Neurologic symptoms associated with parenteral acyclovir treatment after marrow transplantation. Ann Intern Medicine. 1983;98(6):921–925.
12 Haefeli WE, Schoenenberger RA, Weiss P, Ritz RF. Acyclovir-induced neurotoxicity: concentration-side effect relationship in acyclovir overdose. Am J Med. 1993; 94(2):212–215.8430717
13 Hornik CP, Benjamin DK, Becker KC, . Use of the complete blood cell count in late-onset neonatal sepsis. Pediatr Infect Dis J. 2012;31 (8):803–807.22531232