# 14 Tables, Figures, and Graphs Referred to but not Included in the Text

## 14.1 Demographic Data - Tables

Table Number | Population | Table Title
14.1.1.1 | All Enrolled Participants | Participant Accounting and Final Study Disposition by GA/PNA Group
14.1.1.2 | All Enrolled Participants | Participant Enrollment by Site and GA/PNA Group
14.1.1.3 | All Enrolled Participants | Selected Inclusion and Exclusion Criteria by Protocol Version
14.1.2.1 | All Enrolled Participants | Demographic and Baseline Summary by GA/PNA Group
14.1.2.2 | All Enrolled Participants | Summary of Medical History by System Organ Class, Preferred Term and GA/PNA Group
14.1.3.1 | All Enrolled Participants | Number of Protocol Deviations by Site
14.1.3.2 | All Enrolled Participants | Number of Participants with Protocol Deviations by Site
14.1.3.3 | All Enrolled Participants | Summary of Protocol Deviations by Reason Indicated, Deviation Category and Site

## 14.2 Efficacy Data - Tables

14.2.1 | Safety Population | Summary of Microbiology Cultures Before Start of Study Medication by GA/PNA Group
14.2.2 | Safety Population | Summary of Microbiology Cultures After Start of Study Medication by GA/PNA Group

## 14.3 Safety Data - Tables

14.3.1.1 | Safety Population | Summary of Adverse Events by GA/PNA Group
14.3.1.2.1 | Safety Population | Adverse Events by System Organ Class, Preferred Term and GA/PNA Group
14.3.1.2.2 | Safety Population | Serious Adverse Events by System Organ Class, Preferred Term and GA/PNA Group
14.3.1.2.3 | Safety Population | Deaths by System Organ Class, Preferred Term and GA/PNA Group
14.3.1.3 | Safety Population | Adverse Events by System Organ Class, Preferred Term, Severity and GA/PNA Group
14.3.1.4 | Safety Population | Adverse Events by System Organ Class, Preferred Term, Relationship to Study Medication and GA/PNA Group
14.3.1.5 | Safety Population | Adverse Events Listed by Most Frequent Preferred Term and by GA/PNA Group
14.3.1.6 | Safety Population | Listing of Participants with CNS or Renal AEs
14.3.2.1.1 | Safety Population | Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: White Blood Count (10^3^/mm^3^)
14.3.2.1.2 | Safety Population | Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Hematocrit (%)
14.3.2.1.3 | Safety Population | Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Platelet Count (10^3^/mm^3^)
14.3.2.1.4 | Safety Population | Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Neutrophils (%)
14.3.2.1.5 | Safety Population | Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Lymphocytes (%)
14.3.2.1.6 | Safety Population | Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Bands (%)
14.3.2.2.1 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Creatinine (mg/dL)
14.3.2.2.2 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: BUN(Urea) (mg/dL)
14.3.2.2.3 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: AST(SGOT) (U/L)
14.3.2.2.4 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: ALT(SGPT) (U/L)
14.3.2.2.5 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Alkaline Phosphatase (U/L)
14.3.2.2.6 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Total Bilirubin (mg/dL)
14.3.2.2.7 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Direct Bilirubin (mg/dL)
14.3.2.2.8 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Sodium (mmol/L)
14.3.2.2.9 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Potassium (mmol/L)
14.3.2.2.10 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Calcium (mg/dL)
14.3.2.2.11 | Safety Population | Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Albumin (g/dL)
14.3.2.3.1.1 | Safety Population | Summary of Post-baseline Serum Liver Biochemistries Worse-Grade Toxicities by GA and PNA Group
14.3.2.3.1.2 | Safety Population | Summary of Post-baseline Serum Liver Biochemistries Worse-Grade Toxicities by Maxium Dose Group
14.3.2.3.2.1 | Safety Population | Summary of Post-baseline Serum Creatinine Worse-Grade Toxicities by GA and PNA Group
14.3.2.3.2.2 | Safety Population | Summary of Post-baseline Serum Creatinine Worse-Grade Toxicities by Maximum Dose Group
14.3.2.3.3.1 | Safety Population | Summary of Post-baseline Hematology Biochemistries Worse-Grade Toxicities by GA and PNA Group
14.3.2.3.3.2 | Safety Population | Summary of Post-baseline Hematology Biochemistries Worse-Grade Toxicities by Maximum Dose Group
14.3.3 | Safety Population | Summary of Actual Weight (grams) by Visit and GA/PNA Group
14.3.4.1 | Safety Population | Concomitant Medications Before the Start of Study Medication by ATC1 Drug Classification, Drug Name and GA/PNA Group
14.3.4.2 | Safety Population | Concomitant Medications After the Start of Study Medication by ATC1 Drug Classification, Drug Name and GA/PNA Group
14.3.5 | Safety Population | Summary of Abnormal Physical Examination Findings by Body System and GA/PNA Group
14.3.6 | Safety Population | Narratives of Deaths, Other Serious and Certain Other Significant Adverse Events

## 14.4 Dosing and PK – Tables

14.4.1 | All Enrolled Participants | Summary of Study Doses by Protocol Dosing Group
14.4.2 | PK Population | Summary of PK Sampling by GA/PNA Group
14.4.3 | PK Population | Summary of PK Concentration Results by Protocol Dosing Group
14.4.4 | PK Population | Summary of PK Concentration Results for Timed Fresh Plasma Samples by PK Sampling Windows and Protocol Group

## 14.5 Figures

Figure Number | Population | Figure Title
14.1.1 | All Enrolled Participants | Patient Profiles
14.3.1.1 | Safety Population | White Blood Count (10^3^/mm^3^) by Visit - Safety Population
14.3.1.2 | Safety Population | Hematocrit (%) by Visit - Safety Population
14.3.1.3 | Safety Population | Platelet Count (10^3^/mm^3^) by Visit - Safety Population
14.3.1.4 | Safety Population | Neutrophils (%) by Visit - Safety Population
14.3.1.5 | Safety Population | Lymphocytes (%) by Visit - Safety Population
14.3.1.6 | Safety Population | Bands (%) by Visit - Safety Population
14.3.2.1 | Safety Population | Creatinine (mg/dL) by Visit - Safety Population
14.3.2.2 | Safety Population | BUN (mg/dL) by Visit - Safety Population
14.3.2.3 | Safety Population | AST (U/L) by Visit - Safety Population
14.3.2.4 | Safety Population | ALT (U/L) by Visit - Safety Population
14.3.2.5 | Safety Population | Alkaline Phosphatase (U/L) by Visit - Safety Population
14.3.2.6 | Safety Population | Total Bilirubin (mg/dL) by Visit - Safety Population
14.3.2.7 | Safety Population | Direct Bilirubin (mg/dL) by Visit - Safety Population
14.3.2.8 | Safety Population | Sodium (mmol/L) by Visit - Safety Population
14.3.2.9 | Safety Population | Potassium (mmol/L) by Visit - Safety Population
14.3.2.10 | Safety Population | Calcium (mg/dL) by Visit - Safety Population
14.3.2.11 | Safety Population | Albumin (g/dL) by Visit - Safety Population
14.3.3 | Safety Population | Actual Weight by Visit - Safety Population

## 14.6 SAE Narratives

Table 14.1.1.1 Participant Accounting and Final Study Disposition by GA/PNA Group All Enrolled Participants

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Populations
Total Enrolled | 10 (100.0%) | 5 (100.0%) | 9 (100.0%) | 8 (100.0%) | 32 (100.0%)
Enrolled under Protocol V1 | 1 (10.0%) | 1 (20.0%) | 3 (33.3%) | 8 (100.0%) | 13 (40.6%)
Enrolled under Protocol V>=2 | 9 (90.0%) | 4 (80.0%) | 6 (66.7%) | 0 | 19 (59.4%)
>=3 PK samples | 7 (70.0%) | 4 (80.0%) | 7 (77.8%) | 6 (75.0%) | 24 (75.0%)
Evaluable | 7 (70.0%) | 4 (80.0%) | 7 (77.8%) | 0 | 18 (56.3%)
Safety Population | 10 (100.0%) | 5 (100.0%) | 9 (100.0%) | 8 (100.0%) | 32 (100.0%)
PK Population | 10 (100.0%) | 5 (100.0%) | 8 (88.9%) | 7 (87.5%) | 30 (93.8%)
Status of Participants
Completed Study | 6 (60.0%) | 4 (80.0%) | 1 (11.1%) | 0 | 11 (34.4%)
Early Termination | 4 (40.0%) | 1 (20.0%) | 8 (88.9%) | 8 (100.0%) | 21 (65.6%)
Reasons for Early Termination
Adverse event | 1 (10.0%) | 0 | 0 | 1 (12.5%) | 2 (6.3%)
Investigator decision | 1 (10.0%) | 0 | 1 (11.1%) | 0 | 2 (6.3%)
Lost to follow-up | 0 | 0 | 4 (44.4%) | 0 | 4 (12.5%)
Death | 1 (10.0%) | 0 | 0 | 1 (12.5%) | 2 (6.3%)
Culture(s) negative | 1 (10.0%) | 0 | 3 (33.3%) | 6 (75.0%) | 10 (31.3%)
Insufficient sampling | 0 | 1 (20.0%) | 0 | 0 | 1 (3.1%)

Note: Evaluable participants have >=3 fresh plasma PK samples and have gestational age <35 weeks.

Group with GA 35-42 weeks and PNA <14 days was not open in Version <=2.

Safety population includes all participants receiving atleast 1 dose of study acyclovir.

PK population includes all participants contributing atleast 1 fresh plasma sample.

Table 14.1.1.2 Participant Enrollment by Site and GA/PNA Group All Enrolled Participants

Site | Age Strata | | | | Total; (N=32)
Site | GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
▬ | 9 (33.3%) | 1 (3.7%) | 9 (33.3%) | 8 (29.6%) | 27 (100.0%)
▬ | 1 (20.0%) | 4 (80.0%) | 0 | 0 | 5 (100.0%)

Note: NTs in the column header represent number of enrolled participants in each age group for all sites.

The denominator is the total number of participants at the site.

Table 14.1.1.3 Selected Inclusion and Exclusion Criteria by Protocol Version All Enrolled Participants

Criteria | Version 1; (N=13) | Criteria | Version >2; (N=19)
Gestational age (weeks) | | Gestational age (weeks)
N | 13 | N | 19
Mean (SD) | 34.5 (4.8) | Mean (SD) | 27.6 (4.0)
Median (Min, Max) | 35.0 (24.0, 40.0) | Median (Min, Max) | 27.0 (23.0, 34.0)
PNA at first study dose | | PNA at first study dose
N | 13 | N | 19
Mean (SD) | 5.0 (7.0) | Mean (SD) | 7.5 (8.0)
Median (Min, Max) | 3.0 (0.0, 23.0) | Median (Min, Max) | 4.0 (0.0, 30.0)
Dose participant meet the eligibility criteria to be analyzed with Version >=2
No | 8 (61.5%)
Yes | 5 (38.5%)
Weight at time of first study dose (<4500g)
N | 13
Mean (SD) | 2447.7 (1187.8)
Median (Min, Max) | 2150.0 (630.0, 4840.0)
Was infant suspected to have systemic infection with appropriate cultures OR was infant receiving standard of care acyclovir? | | Is infant suspected to have HSV sepsis OR is the infant experiencing 2 or more qualifying conditions?
No | 0 | No | 0
Yes-suspected infection | 6 (46.2%) | Yes-suspected HIV infection | 6 (31.6%)
Yes SOC acyclovir | 7 (53.8%) | Yes-2 or more conditions | 13 (68.4%)
| | Is the infant receiving standard of care acyclovir?
| | No | 13 (68.4%)
| | Yes | 6 (31.6%)
Did the participant have a serum creatinine level >1.7mg/dL? | | Did the participant have a serum creatinine level >1.7mg/dL?
No | 10 (76.9%) | No | 17 (89.5%)
Yes | 0 | Yes | 1 (5.3%)
Not Done | 3 (23.1%) | Not Done | 1 (5.3%)
Did the participant meet the above eligibility criteria? | | Did the participant meet the above eligibility criteria?
No | 1 (7.7%) | No | 2 (10.5%)
Yes | 12 (92.3%) | Yes | 17 (89.5%)
Did the investigator request a waiver? | | Did the investigator request a waiver?
No | 1 (7.7%) | No | 2 (10.5%)
Yes | 0 | Yes | 0

Table 14.1.2.1 Demographic and Baseline Summary by GA/PNA Group All Enrolled Participants

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Gestational Age (weeks)
N | 10 | 5 | 9 | 8 | 32
Mean (SD) | 26.2 (1.8) | 23.6 (0.5) | 32.6 (1.6) | 37.5 (2.0) | 30.4 (5.5)
95% CI of the Mean | 24.9, 27.5 | 22.9, 24.3 | 31.3, 33.8 | 35.8, 39.2 | 28.4, 32.4
Median (Min-Max) | 26.0 (24.0, 29.0) | 24.0 (23.0, 24.0) | 33.0 (30.0, 34.0) | 38.0 (35.0, 40.0) | 30.5 (23.0, 40.0)
Postnatal Age (days)
N | 10 | 5 | 9 | 8 | 32
Mean (SD) | 5.2 (3.8) | 20.8 (6.5) | 3.6 (5.1) | 2.5 (2.5) | 6.5 (7.6)
95% CI of the Mean | 2.5, 7.9 | 12.7, 28.9 | 0.0, 7.4 | 0.4, 4.6 | 3.8, 9.2
Median (Min-Max) | 3.5 (1.0, 12.0) | 22.0 (14.0, 30.0) | 2.0 (0.0, 16.0) | 2.0 (0.0, 8.0) | 3.0 (0.0, 30.0)
Birth Length (cm)
N | | 5 | 9 | 8 | 32
Mean (SD) | 33.9 (4.4) | 30.8 (1.5) | 40.9 (5.1) | 49.9 (3.6) | 39.4 (8.1)
95% CI of the Mean | 30.7, 37.1 | 29.0, 32.6 | 37.0, 44.8 | 46.9, 52.9 | 36.4, 42.3
Median (Min-Max) | 33.5 (27.0, 40.0) | 31.0 (29.0, 33.0) | 43.0 (30.0, 46.0) | 49.0 (45.0, 57.0) | 40.0 (27.0, 57.0)
Birth Weight (grams)
N | 10 | 5 | 9 | 8 | 32
Mean (SD) | 839 (276) | 683 (157) | 1725 (556) | 3142 (919) | 1640 (1111)
95% CI of the Mean | 641, 1037 | 488, 878 | 1298, 2152 | 2373, 3911 | 1239, 2040
Median (Min-Max) | 790 (420, 1270) | 630 (510, 914) | 1770 (800, 2645) | 3138 (1980, 4840) | 1295 (420, 4840)
Weight at Baseline (grams)
N | 10 | 5 | 9 | 8 | 32
Mean (SD) | 872 (323) | 864 (162) | 1725 (537) | 3165 (911) | 1684 (1088)
95% CI of the Mean | 641, 1103 | 663, 1066 | 1312, 2138 | 2404, 3926 | 1292, 2076
Median (Min-Max) | 810 (440, 1560) | 810 (703, 1100) | 1770 (800, 2645) | 3138 (2060, 4840) | 1400 (440, 4840)
Gender
Male | 2 (20.0%) | 3 (60.0%) | 5 (55.6%) | 5 (62.5%) | 15 (46.9%)
Female | 8 (80.0%) | 2 (40.0%) | 4 (44.4%) | 3 (37.5%) | 17 (53.1%)
Ethnicity^*^
Hispanic or Latino | 2 (20.0%) | 1 (20.0%) | 1 (11.1%) | 0 | 4 (12.5%)
Not Hispanic or Latino | 8 (80.0%) | 4 (80.0%) | 8 (88.9%) | 8 (100.0%) | 28 (87.5%)
Race^*^
Asian | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Black or African American | 5 (50.0%) | 2 (40.0%) | 2 (22.2%) | 2 (25.0%) | 11 (34.4%)
White or Caucasian | 5 (50.0%) | 3 (60.0%) | 7 (77.8%) | 5 (62.5%) | 20 (62.5%)

Note:

* Version 1 participants report maternal race and ethnicity; Version >= 2 participants report participant race and ethnicity.

Table 14.1.2.2 Summary of Medical History by System Organ Class, Preferred Term and by GA/PNA Group All Enrolled Participants

System Organ Class; Preferred Term | Age Strata
System Organ Class; Preferred Term | GA 23-29 weeks; PNA <14 days; (N=10) | | GA 23-29 weeks; PNA 14-44 days; (N=5) | | GA 30-34 weeks; PNA <45 days; (N=9) | | GA 35-42 weeks; PNA <14 days; (N=8) | | All Participants; (N=32)
System Organ Class; Preferred Term | Participants With Medical History N (%) | Total Medical History N | Participants With Medical History N (%) | Total Medical History N | Participants With Medical History N (%) | Total Medical History N | Participants With Medical History N (%) | Total Medical History N | Participants With Medical History N (%) | Total Medical History N
Blood and lymphatic system disorders | 7 (70%) | 10 | 5 (100%) | 8 | 0 | 0 | 2 (25%) | 2 | 14 (43.8%) | 20
Anaemia | 0 | 0 | 4 (80%) | 4 | 0 | 0 | 0 | 0 | 4 (12.5%) | 4
Anaemia neonatal | 3 (30%) | 3 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 4 (12.5%) | 4
Coagulopathy | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Disseminated intravascular coagulation in newborn | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Leukopenia | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Neutropenia | 3 (30%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (9.4%) | 3
Thrombocytopenia | 0 | 0 | 2 (40%) | 2 | 0 | 0 | 2 (25%) | 2 | 4 (12.5%) | 4
Thrombocytopenia neonatal | 2 (20%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Cardiac disorders | 0 | 0 | 1 (20%) | 1 | 1 (11.1%) | 1 | 0 | 0 | 2 (6.3%) | 2
Arrhythmia | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Tachycardia | 0 | | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Congenital, familial and genetic disorders | 7 (70%) | 12 | 4 (80%) | 5 | 2 (22.2%) | 3 | 3 (37.5%) | 10 | 16 (50%) | 30
Atrial septal defect | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 2 (6.3%) | 2
Chromosomal deletion | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Congenital anaemia | 1 (10%) | 1 | 3 (60%) | 3 | 0 | 0 | 0 | 0 | 4 (12.5%) | 4
Congenital anomaly | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Congenital cystic kidney disease | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Congenital diaphragmatic hernia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Congenital oral malformation | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Gastroschisis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 2 | 1 (3.1%) | 2
Heart disease congenital | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Hydrocele | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Infantile genetic agranulocytosis | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Microcephaly | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Micropenis | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Patent ductus arteriosus | 2 (20%) | 2 | 2 (40%) | 2 | 0 | 0 | 1 (12.5%) | 1 | 5 (15.6%) | 5
Persistent foetal circulation | 2 (20%) | 2 | 0 | 0 | 1 (11.1%) | 1 | 1 (12.5%) | 1 | 4 (12.5%) | 4
Pilonidal cyst congenital | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 2 (6.3%) | 2
Ventricular septal defect | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Endocrine disorders | 0 | 0 | 2 (40%) | 2 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Adrenal insufficiency | 0 | 0 | 2 (40%) | 2 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Gastrointestinal disorders | 2 (20%) | 2 | 2 (40%) | 2 | 0 | 0 | 1 (12.5%) | 1 | 5 (15.6%) | 5
Acute abdomen | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Ascites | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Gastrointestinal perforation | 0 | 0 | 2 (40%) | 2 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Short-bowel syndrome | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
General disorders and administration site conditions | 2 (20%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Adverse drug reaction | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Drug withdrawal syndrome | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Hepatobiliary disorders | 8 (80%) | 8 | 5 (100%) | 7 | 4 (44.4%) | 5 | 3 (37.5%) | 3 | 20 (62.5%) | 23
Hyperbilirubinaemia | 3 (30%) | 3 | 5 (100%) | 5 | 2 (22.2%) | 2 | 2 (25%) | 2 | 12 (37.5%) | 12
Hyperbilirubinaemia neonatal | 5 (50%) | 5 | 0 | 0 | 2 (22.2%) | 2 | 0 | 0 | 7 (21.9%) | 7
Hypoalbuminaemia | 0 | 0 | 2 (40%) | 2 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Jaundice | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (12.5%) | 1 | 2 (6.3%) | 2
Immune system disorders | 1 (10%) | 1 | 0 | 0 | 1 (11.1%) | 1 | 1 (12.5%) | 1 | 3 (9.4%) | 3
ABO incompatibility | 1 (10%) | 1 | 0 | 0 | 1 (11.1%) | 1 | 1 (12.5%) | 1 | 3 (9.4%) | 3
Infections and infestations | 3 (30%) | 3 | 3 (60%) | 3 | 1 (11.1%) | 1 | 0 | 0 | 7 (21.9%) | 7
Abdominal abscess | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Hepatitis A | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Pneumonia | 1 (10%) | 1 | 1 (20%) | 1 | 1 (11.1%) | 1 | 0 | 0 | 3 (9.4%) | 3
Sepsis | 1 (10%) | 1 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Injury, poisoning and procedural complications | 2 (20%) | 2 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 3 (9.4%) | 3
Contusion | 2 (20%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Maternal exposure timing unspecified | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Investigations | 1 (10%) | 1 | 1 (20%) | 1 | 0 | 0 | 2 (25%) | 2 | 4 (12.5%) | 4
Liver function test abnormal | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 2 (6.3%) | 2
Metabolic function test abnormal | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Nuclear magnetic resonance imaging abnormal | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Metabolism and nutrition disorders | 7 (70%) | 10 | 4 (80%) | 10 | 4 (44.4%) | 6 | 3 (37.5%) | 3 | 18 (56.3%) | 29
Adrenal insufficiency | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Feeding disorder neonatal | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Hyperglycaemia | 3 (30%) | 3 | 2 (40%) | 2 | 1 (11.1%) | 1 | 0 | 0 | 6 (18.8%) | 6
Hyperkalaemia | 3 (30%) | 3 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 4 (12.5%) | 4
Hypermagnesaemia | 1 (10%) | 1 | 0 | 0 | 2 (22.2%) | 2 | 0 | 0 | 3 (9.4%) | 3
Hypoalbuminaemia | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Hypoglycaemia | 0 | 0 | 1 (20%) | 1 | 1 (11.1%) | 1 | 1 (12.5%) | 1 | 3 (9.4%) | 3
Hypoglycaemia neonatal | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Hyponatraemia | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Lactic acidosis | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (12.5%) | 1 | 2 (6.3%) | 2
Metabolic acidosis | 1 (10%) | 1 | 4 (80%) | 4 | 0 | 0 | 1 (12.5%) | 1 | 6 (18.8%) | 6
Musculoskeletal and connective tissue disorders | 0 | 0 | 1 (20%) | 2 | 0 | 0 | 0 | 0 | 1 (3.1%) | 2
Osteopenia | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Spinal disorder | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Nervous system disorders | 2 (20%) | 3 | 4 (80%) | 5 | 1 (11.1%) | 1 | 5 (62.5%) | 6 | 12 (37.5%) | 15
Convulsion | 1 (10%) | 1 | 4 (80%) | 4 | 0 | 0 | 4 (50%) | 4 | 9 (28.1%) | 9
Haemorrhage intracranial | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Hydrocephalus | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Hypotonia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Intraventricular haemorrhage | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Intraventricular haemorrhage neonatal | 1 (10%) | 1 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Pregnancy, puerperium and perinatal conditions | 8 (80%) | 17 | 0 | 0 | 7 (77.8%) | 8 | 3 (37.5%) | 5 | 18 (56.3%) | 30
Foetal growth restriction | 2 (20%) | 2 | 0 | 0 | 1 (11.1%) | 1 | 1 (12.5%) | 1 | 4 (12.5%) | 4
Hydrops foetal is | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Large for dates baby | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Low birth weight baby | 3 (30%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (9.4%) | 3
Maternal condition affecting foetus | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Premature baby | 8 (80%) | 8 | 0 | 0 | 6 (66.7%) | 6 | 0 | 0 | 14 (43.8%) | 14
Sepsis neonatal | 3 (30%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (9.4%) | 3
Small for dates baby | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (12.5%) | 2 | 2 (6.3%) | 3
Renal and urinary disorders | 2 (20%) | 3 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 3 (9.4%) | 4
Haematuria | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Oliguria | 1 (10%) | 1 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Renal failure | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Respiratory, thoracic and mediastinal disorders | 9 (90%) | 15 | 5 (100%) | 9 | 7 (77.8%) | 12 | 4 (50%) | 5 | 25 (78.1%) | 41
Acute pulmonary oedema | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Apnoea | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Infantile apnoeic attack | 4 (40%) | 4 | 4 (80%) | 4 | 5 (55.6%) | 5 | 1 (12.5%) | 1 | 14 (43.8%) | 14
Neonatal asphyxia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Neonatal respiratory depression | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Neonatal respiratory distress syndrome | 8 (80%) | 8 | 5 (100%) | 5 | 3 (33.3%) | 3 | 1 (12.5%) | 1 | 17 (53.1%) | 17
Pleural effusion | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Pneumothorax | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (12.5%) | 1 | 2 (6.3%) | 2
Pulmonary oedema | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Respiratory failure | 1 (10%) | 1 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 2 (6.3%) | 2
Surgical and medical procedures | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 1 (12.5%) | 1 | 2 (6.3%) | 2
Gastrointestinal tube insertion | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Intestinal resection | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Vascular disorders | 4 (40%) | 5 | 4 (80%) | 5 | 1 (11.1%) | 1 | 2 (25%) | 2 | 11 (34.4%) | 13
Hypertension | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Hypotension | 4 (40%) | 4 | 4 (80%) | 4 | 1 (11.1%) | 1 | 2 (25%) | 2 | 11 (34.4%) | 11
Intraventricular haemorrhage neonatal | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1

Note: The percentages are based on the total number of participants in each GA/PNA group or total.

Participants are counted once at each System Organ Class and Preferred Term levels.

Table 14.1.3.1 Number of Protocol Deviations by Site All Enrolled Participants

Site | Informed Consent | Eligibility Enrollment | Study Medication Administration | Protocol Procedure/Assessment | Other | Total
Total | 1 | 7 | 8 | 15 | 1 | 32
▬ | 1 | 5 | 7 | 14 | 1 | 28
▬ | 0 | 2 | 1 | 1 | 0 | 4

Table 14.1.3.2 Number of Participants with Protocol Deviations by Site All Enrolled Participants

Site | Informed Consent | Eligibility Enrollment | Study Medication Administration | Protocol Procedure/Assessment | Other | Total Participants with Deviations
Total | 1 (3.1%) | 7 (21.9%) | 7 (21.9%) | 12 (37.5%) | 1 (3.1%) | 23 (71.9%)
▬ | 1 (3.7%) | 5 (18.5%) | 6 (22.2%) | 11 (40.7%) | 1 (3.7%) | 19 (70.4%)
▬ | 0 | 2 (40.0%) | 1 (20.0%) | 1 (20.0%) | 0 | 4 (80.0%)

Table 14.1.3.3 Summary of Protocol Deviations by Reason Indicated, Deviation Category and Site All Enrolled Participants

All Centers (n=32) | Hospital error | | Research staff/clinic error | | Laboratory error | | PI decision | | Total
Deviation Category | #of Participants | #of Deviations | #of Participants | #of Deviations | #of Participants | #of Deviations | #of Participants | #of Deviations | #of Participants | #of Deviations
Total | 12 | 16 | 10 | 11 | 1 | 1 | 4 | 4 | 23 | 32
Informed consent/assent | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 1
Eligibility/enrollment | 0 | 0 | 3 | 3 | 0 | 0 | 4 | 4 | 7 | 7
Study medication administration | 6 | 7 | 1 | 1 | 0 | 0 | 0 | 0 | 7 | 8
Protocol procedure/assessment | 7 | 9 | 5 | 5 | 1 | 1 | 0 | 0 | 12 | 15
Other | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 1

RE (n=27) | Hospital error | | Research staff/clinic error | | Laboratory error | | PI decision | | Total
Deviation Category | # of Participants | # of Deviations | # of Participants | # of Deviations | # of Participants | # of Deviations | # of Participants | # of Deviations | # of Participants | # of Deviations
Total | 12 | 16 | 7 | 8 | 0 | 0 | 4 | 4 | 19 | 28
Informed consent/assent | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 1
Eligibility/enrollment | 0 | 0 | 1 | 1 | 0 | 0 | 4 | 4 | 5 | 5
Study medication administration | 6 | 7 | 0 | 0 | 0 | 0 | 0 | 0 | 6 | 7
Protocol procedure/assessment | 7 | 9 | 5 | | 0 | 0 | 0 | 0 | 11 | 14
Other | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 1

RED (n=5) | Hospital error | | Research staff/clinic error | | Laboratory error | | PI decision | | Total
Deviation Category | #of Participants | #of Deviations | #of Participants | #of Deviations | #of Participants | #of Deviations | #of Participants | #of Deviations | #of Participants | #of Deviations
Total | 0 | 0 | 3 | 3 | 1 | 1 | 0 | 0 | 4 | 4
Eligibility/enrollment | 0 | 0 | 2 | 2 | 0 | 0 | 0 | 0 | 2 | 2
Study medication administration | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 1
Protocol procedure/assessment | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 1 | 1

Table 14.2.1 Summary of Microbiology Cultures Before Start of Study Medication by GA/PNA Group Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Total Number of Cultures | 20 | 19 | 21 | 12 | 72
Number of Participants with Cultures
N | 10 | 5 | 9 | 6 | 30
Mean (SD) Cultures per Participant | 2.0 (1.2) | 3.8 (0.8) | 2.3 (1.3) | 2.0 (0.9) | 2.4 (1.2)
Median (Min, Max) Cultures per Participant | 1.5 (1.0, 4.0) | 4.0 (3.0, 5.0) | 2.0 (1.0, 5.0) | 2.0 (1.0, 3.0) | 2.5 (1.0, 5.0)
Cultures
Blood culture | 7 | 9 | 7 | 5 | 28
Cerebrospinal fluid PCR - HSV | 1 | 3 | 1 | 1 | 6
Cerebrospinal fluid culture | 0 | 3 | 3 | 2 | 8
HSV surface culture | 5 | 2 | 6 | 3 | 16
MRSA nasal | 6 | 0 | 3 | 0 | 9
Urine culture | 1 | 2 | 1 | 1 | 5
Method of Acquisition
Bag | 0 | 0 | 0 | 1 | 1
Catheterization | 1 | 2 | 1 | 0 | 4
Central line | 0 | 0 | 1 | 0 | 1
Cutaneous swab | 11 | 2 | 9 | 3 | 25
Lumbar puncture | 1 | 6 | 4 | 3 | 14
Peripheral | 7 | 9 | 5 | 5 | 26
not stated in report | 0 | 0 | 1 | 0 | 1
Culture Results
Missing | 2 | 0 | 0 | 0 | 2
Negative | 18 | 18 | 21 | 12 | 69
Positive | 0 | 1 | 0 | 0 | 1
Type of Organism* in Positive Cultures
Escherichia coli | 0 | 1 | 0 | 0 | 1

Note: Cultures can be positive for more than 1 organism.

Table 14.2.2 Summary of Microbiology Cultures After Start of Study Medication by GA/PNA Group Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Total Number of Cultures | 8 | 1 | 3 | 1 | 13
Number of Participants with Cultures
N | 5 | 1 | 2 | 1 | 9
Mean (SD) Cultures per Participant | 1.6 (0.5) | 1.0 | 1.5 (0.7) | 1.0 | 1.4 (0.5)
Median (Min, Max) Cultures per Participant | 2.0 (1.0, 2.0) | 1.0 | 1.5 (1.0, 2.0) | 1.0 | 1.0 (1.0, 2.0)
Cultures
Blood culture | 2 | 0 | 0 | 0 | 2
Cerebrospinal fluid PCR - HSV | 0 | 1 | 0 | 0 | 1
Cerebrospinal fluid culture | 0 | 0 | 0 | 1 | 1
Endotracheal suction bacteria culture | 1 | 0 | 0 | 0 | 1
HSV surface culture | 2 | 0 | 1 | 0 | 3
MRSA nasal | 3 | 0 | 1 | 0 | 4
Urine culture | 0 | 0 | 1 | 0 | 1
Method of Acquisition
Bag | 0 | 0 | 1 | 0 | 1
Cutaneous swab | 5 | 0 | 2 | 0 | 7
Entrotracheal | 1 | 0 | 0 | 0 | 1
Lumbar puncture | 0 | 1 | 0 | 1 | 2
Peripheral | 2 | 0 | 0 | 0 | 2
Culture Results
Negative | 7 | 1 | 3 | 1 | 12
Positive | 1 | 0 | 0 | 0 | 1
Type of Organism* in Positive Cultures
3 gram postive cocci | 1 | 0 | 0 | 0 | 1
4 oropharyngeal flora | 1 | 0 | 0 | 0 | 1

Note: Cultures can be positive for more than 1 organism.

Table 14.3.1.1 Summary of Adverse Events by GA/PNA Group Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Number of Events/Participants
Number of Adverse Events | 24 | 3 | 6 | 5 | 38
Participants with at least one AE | 9 (90.0%) | 3 (60.0%) | 5 (55.6%) | 4 (50.0%) | 21 (65.6%)
Number of SAEs | 1 | 0 | 0 | 3 | 4
Participants with at least one SAE | 1 (10.0%) | 0 | 0 | 3 (37.5%) | 4 (12.5%)
Severity (All AEs)
Mild | 19 | 1 | 5 | 1 | 26
Moderate | 4 | 2 | 1 | 1 | 8
Severe | 1 | 0 | 0 | 3 | 4
Highest Severity Per Participant
Mild | 5 (50.0%) | 1 (20.0%) | 4 (44.4%) | 1 (12.5%) | 11 (34.4%)
Moderate | 3 (30.0%) | 2 (40.0%) | 1 (11.1%) | 0 | 6 (18.8%)
Severe | 1 (10.0%) | 0 | 0 | 3 (37.5%) | 4 (12.5%)
Relationship (All AEs)
Not-related | 23 | 3 | 6 | 5 | 37
Related | 1 | 0 | 0 | 0 | 1
Strongest Relationship Per Participant
Not-related | 8 (80.0%) | 3 (60.0%) | 5 (55.6%) | 4 (50.0%) | 20 (62.5%)
Related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Severity (All SAEs)
Severe | 1 | 0 | 0 | 3 | 4
Relationship (All SAEs)
Not-related | 1 | 0 | 0 | 3 | 4

Table 14.3.1.2.1 Adverse Events by System Organ Class, Preferred Term and GA/PNA Group Safety Population

System Organ Class; Preferred Term | Age Strata
System Organ Class; Preferred Term | GA 23-29 weeks; PNA <14 days; (N=10) | | GA 23-29 weeks; PNA 14-44 days; (N=5) | | GA 30-34 weeks; PNA <45 days; (N=9) | | GA 35-42 weeks; PNA <14 days; (N=8) | | All Participants; (N=32)
System Organ Class; Preferred Term | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N
Blood and lymphatic system disorders | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Haemolytic anaemia | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Cardiac disorders | 0 | 0 | 0 | 1 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Cardiomegaly | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Congenital, familial and genetic disorders | 4 (40%) | 5 | 0 | 0 | 1 (11.1%) | 1 | 1 (12.5%) | 1 | 6 (18.8%) | 7
Atrial septal defect | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Congenital cardiovascular anomaly | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Nonketotic hyperglycinaemia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Patent ductus arteriosus | 3 (30%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (9.4%) | 3
Ventricular septal defect | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Endocrine disorders | 3 (30%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (9.4%) | 3
Adrenal insufficiency | 3 (30%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (9.4%) | 3
Hepatobiliary disorders | 0 | 0 | 0 | 0 | 2 (22.2%) | 2 | 0 | 0 | 2 (6.3%) | 2
Hyperbilirubinaemia | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Hyperbilirubinaemia neonatal | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Infections and infestations | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Sepsis | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Investigations | 2 (20%) | 2 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 3 (9.4%) | 3
Blood creatinine abnormal | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Blood creatinine increased | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Electrocardiogram QT prolonged | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Metabolism and nutrition disorders | 3 (30%) | 5 | 2 (40%) | 2 | 0 | 0 | 1 (12.5%) | 1 | 6 (18.8%) | 8
Electrolyte imbalance | 1 (10%) | | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Hyperglycaemia | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Hyperkalaemia | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 2 (6.3%) | 2
Hypoalbuminaemia | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Hypocalcaemia | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Neonatal hyponatraemia | 1 (10%) | 1 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Neuroblastoma | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Nervous system disorders | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Intraventricular haemorrhage neonatal | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Renal and urinary disorders | 2 (20%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Renal failure | 2 (20%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Respiratory, thoracic and mediastinal disorders | 3 (30%) | 3 | 1 (20%) | 1 | 2 (22.2%) | 2 | 1 (12.5%) | 1 | 7 (21.9%) | 7
Apnoea | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Chronic respiratory disease | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Infantile apnoeic attack | 1 (10%) | 1 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 2 (6.3%) | 2
Neonatal asphyxia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Pleural effusion | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Respiratory distress | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 1 (3.1%) | 1
Skin and subcutaneous tissue disorders | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Dermatitis diaper | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1

Table 14.3.1.2.2 Serious Adverse Events by System Organ Class, Preferred Term and GA/PNA Group Safety Population

System Organ Class; Preferred Term | Age Strata
System Organ Class; Preferred Term | GA 23-29 weeks; PNA <14 days; (N=10) | | GA 23-29 weeks; PNA 14-44 days; (N=5) | | GA 30-34 weeks; PNA <45 days; (N=9) | | GA 35-42 weeks; PNA <14 days; (N=8) | | All Participants; (N=32)
System Organ Class; Preferred Term | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N
Congenital, familial and genetic disorders | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Nonketotic hyperglycinaemia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Infections and infestations | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Sepsis | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Neuroblastoma | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Respiratory, thoracic and mediastinal disorders | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Neonatal asphyxia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1

Table 14.3.1.2.3 Deaths by System Organ Class, Preferred Term and GA/PNA Group Safety Population

System Organ Class; Preferred Term | Age Strata
System Organ Class; Preferred Term | GA 23-29 weeks; PNA <14 days; (N=10) | | GA 23-29 weeks; PNA 14-44 days; (N=5) | | GA 30-34 weeks; PNA <45 days; (N=9) | | GA 35-42 weeks; PNA <14 days; (N=8) | | All Participants; (N=32)
System Organ Class; Preferred Term | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N
Congenital, familial and genetic disorders | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Nonketotic hyperglycinaemia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 1 (3.1%) | 1
Infections and infestations | 1 (10%) | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
Sepsis | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1

Table 14.3.1.3 Adverse Events by System Organ Class, Preferred Term, Severity and GA/PNA Group Safety Population

System Organ Class; Preferred Term | Severity | Age Strata | | | | Total; (N=32)
System Organ Class; Preferred Term | Severity | GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Blood and lymphatic system disorders | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Haemolytic anaemia | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Cardiac disorders | Moderate | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Cardiomegaly | Moderate | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Congenital, familial and genetic disorders | Mild | 2 (20.0%) | 0 | 1 (11.1%) | 0 | 3 (9.4%)
| Moderate | 2 (20.0%) | 0 | 0 | 0 | 2 (6.3%)
| Severe | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Atrial septal defect | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Congenital cardiovascular anomaly | Mild | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Nonketotic hyperglycinaemia | Severe | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Patent ductus arteriosus | Mild | 2 (20.0%) | 0 | 0 | 0 | 2 (6.3%)
| Moderate | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Ventricular septal defect | Moderate | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Endocrine disorders | Mild | 3 (30.0%) | 0 | 0 | 0 | 3 (9.4%)
Adrenal insufficiency | Mild | 3 (30.0%) | 0 | 0 | 0 | 3 (9.4%)
Hepatobiliary disorders | Mild | 0 | 0 | 2 (22.2%) | 0 | 2 (6.3%)
Hyperbilirubinaemia | Mild | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Hyperbilirubinaemia neonatal | Mild | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Infections and infestations | Severe | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Sepsis | Severe | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Investigations | Mild | 1 (10.0%) | 0 | 1 (11.1%) | 0 | 2 (6.3%)
| Moderate | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Blood creatinine abnormal | Moderate | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Blood creatinine increased | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Electrocardiogram QT prolonged | Mild | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Metabolism and nutrition disorders | Mild | 2 (20.0%) | 1 (20.0%) | 0 | 1 (12.5%) | 4 (12.5%)
| Moderate | 1 (10.0%) | 1 (20.0%) | 0 | 0 | 2 (6.3%)
Electrolyte imbalance | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Hyperglycaemia | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Hyperkalaemia | Mild | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
| Moderate | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Hypoalbuminaemia | Moderate | 0 | 1 (20.0%) | 0 | 0 | 1 (3.1%)
Hypocalcaemia | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Neonatal hyponatraemia | Mild | 1 (10.0%) | 1 (20.0%) | 0 | 0 | 2 (6.3%)
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | Severe | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Neuroblastoma | Severe | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Nervous system disorders | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Intraventricular haemorrhage neonatal | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Renal and urinary disorders | Mild | 2 (20.0%) | 0 | 0 | 0 | 2 (6.3%)
Renal failure | Mild | 2 (20.0%) | 0 | 0 | 0 | 2 (6.3%)
Respiratory, thoracic and mediastinal disorders | Mild | 3 (30.0%) | 0 | 1 (11.1%) | 0 | 4 (12.5%)
| Moderate | 0 | 1 (20.0%) | 1 (11.1%) | 0 | 2 (6.3%)
| Severe | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Apnoea | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Chronic respiratory disease | Moderate | 0 | 1 (20.0%) | 0 | 0 | 1 (3.1%)
Infantile apnoeic attack | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
| Moderate | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Neonatal asphyxia | Severe | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Pleural effusion | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Respiratory distress | Mild | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Skin and subcutaneous tissue disorders | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Dermatitis diaper | Mild | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)

Note: The percentages are based on the total number of participants in each GA/PNA group or total.

Participants are counted once at each System Organ Class and Preferred Term levels using the highest severity.

Table 14.3.1.4 Adverse Events by System Organ Class, Preferred Term, Relationship to Study Medication and GA/PNA Group Safety Population

System Organ Class; Preferred Term | Relationship | Age Strata | | | | Total; (N=32)
System Organ Class; Preferred Term | Relationship | GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Blood and lymphatic system disorders | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Haemolytic anaemia | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Cardiac disorders | Not-related | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Cardiomegaly | Not-related | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Congenital, familial and genetic disorders | Not-related | 4 (40.0%) | 0 | 1 (11.1%) | 1 (12.5%) | 6 (18.8%)
Atrial septal defect | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Congenital cardiovascular anomaly | Not-related | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Nonketotic hyperglycinaemia | Not-related | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Patent ductus arteriosus | Not-related | 3 (30.0%) | 0 | 0 | 0 | 3 (9.4%)
Ventricular septal defect | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Endocrine disorders | Not-related | 3 (30.0%) | 0 | 0 | 0 | 3 (9.4%)
Adrenal insufficiency | Not-related | 3 (30.0%) | 0 | 0 | 0 | 3 (9.4%)
Hepatobiliary disorders | Not-related | 0 | 0 | 2 (22.2%) | 0 | 2 (6.3%)
Hyperbilirubinaemia | Not-related | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Hyperbilirubinaemia neonatal | Not-related | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Infections and infestations | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Sepsis | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Investigations | Not-related | 1 (10.0%) | 0 | 1 (11.1%) | 0 | 2 (6.3%)
| Related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Blood creatinine abnormal | Related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Blood creatinine increased | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Electrocardiogram QT prolonged | Not-related | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Metabolism and nutrition disorders | Not-related | 3 (30.0%) | 2 (40.0%) | 0 | 1 (12.5%) | 6 (18.8%)
Electrolyte imbalance | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Hyperglycaemia | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Hyperkalaemia | Not-related | 1 (10.0%) | 0 | 0 | 1 (12.5%) | 2 (6.3%)
Hypoalbuminaemia | Not-related | 0 | 1 (20.0%) | 0 | 0 | 1 (3.1%)
Hypocalcaemia | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Neonatal hyponatraemia | Not-related | 1 (10.0%) | 1 (20.0%) | 0 | 0 | 2 (6.3%)
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | Not-related | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Neuroblastoma | Not-related | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Nervous system disorders | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Intraventricular haemorrhage neonatal | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Renal and urinary disorders | Not-related | 2 (20.0%) | 0 | 0 | 0 | 2 (6.3%)
Renal failure | Not-related | 2 (20.0%) | 0 | 0 | 0 | 2 (6.3%)
Respiratory, thoracic and mediastinal disorders | Not-related | 3 (30.0%) | 1 (20.0%) | 2 (22.2%) | 1 (12.5%) | 7 (21.9%)
Apnoea | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Chronic respiratory disease | Not-related | 0 | 1 (20.0%) | 0 | 0 | 1 (3.1%)
Infantile apnoeic attack | Not-related | 1 (10.0%) | 0 | 1 (11.1%) | 0 | 2 (6.3%)
Neonatal asphyxia | Not-related | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Pleural effusion | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Respiratory distress | Not-related | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Skin and subcutaneous tissue disorders | Not-related | 1 (10.0%) | 00 | 0 | 0 | 1 (3.1%)
Dermatitis diaper | Not-related | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)

Note: The percentages are based on the total number of participants in each GA/PNA group or total.

Participants are counted once at each System Organ Class and Preferred Term levels using the closest relationship to study drug.

Table 14.3.1.5 Adverse Events Listed by Most Frequent Preferred Term and by GA/PNA Group Safety Population

System Organ Class | Preferred Term | Age Strata
System Organ Class | Preferred Term | GA 23-29 weeks; PNA <14 days; (N=10) | | GA 23-29 weeks; PNA 14-44 days; (N=5) | | GA 30-34 weeks; PNA <45 days; (N=9) | | GA 35-42 weeks; PNA <14 days; (N=8) | | All Participants; (N=32)
System Organ Class | Preferred Term | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N
Endocrine disorders | Adrenal insufficiency | 3 (30%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (9.4%) | 3
Congenital, familial and genetic disorders | Patent ductus arteriosus | 3 (30%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (9.4%) | 3
Metabolism and nutrition disorders | Hyperkalaemia | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 | 2 (6.3%) | 2
Respiratory, thoracic and mediastinal disorders | Infantile apnoeic attack | 1 (10%) | 1 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 2 (6.3%) | 2
Metabolism and nutrition disorders | Neonatal hyponatraemia | 1 (10%) | | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2
Renal and urinary disorders | Renal failure | 2 (20%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (6.3%) | 2

Note: Events that occurred in 5% or more participants are included.

Table 14.3.1.6 Listing of Participants with CNS or Renal AEs Participant ID: ▬

Date | Dose (mg/kg/day) | Preferred Term | System Organ Class | Severity | Relationship | Outcome | Serum Creatinine (mg/dL)
▬ | . | | | | | | 1.1
▬ | 10 | | | | | | 1.1
▬ | 20 | Renal failure | Renal and urinary disorders | Mild | Not-related | Resolved by convention | 1.2
▬ | 22 | | | | | | 1.1
▬ | 11 | | | | | | 1.2
▬ | . | | | | | | 1
▬ | 10 | | | | | | 1.2
▬ | 24 | | | | | | 1.5
▬ | . | | | | | | 1.8
▬ | . | Renal failure | Renal and urinary disorders | Mild | Not-related | Resolved | .
▬ | . | | | | | | 1
▬ | 11 | | | | | | .
▬ | 24 | | | | | | 0.9
▬ | 24 | | | | | | 0.9
▬ | 12 | | | | | | 1
▬ | . | Intraventricular haemorrhage neonatal | Nervous system disorders | Mild | Not-related | Resolved by convention | .

Table 14.3.2.1.1 Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: White Blood Count (10^3^/mm^3^) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 9 | 5 | 7 | 7 | 28
Mean (SD) | 11.1 (4.4) | 12.8 (5.8) | 10.4 (4.8) | 16.9 (5.9) | 12.7 (5.5)
95% CI of the Mean | 7.7, 14.5 | 5.6, 20.0 | 6.0, 14.9 | 11.5, 22.4 | 10.5, 14.8
Median (Min-Max) | 11.5 (3.2, 18.6) | 11.0 (7.4, 22.6) | 10.0 (3.6, 17.2) | 14.3 (8.9, 25.3) | 12.3 (3.2, 25.3)
Day 1
N | 3 | 1 | 3 | 5 | 12
Mean (SD) | 11.4 (10.2) | 2.9 | 6.5 (3.0) | 11.6 (4.6) | 9.5 (6.1)
95% CI of the Mean | 0.0, 36.6 | 0 | 0.0, 13.9 | 5.9, 17.2 | 5.7, 13.4
Median (Min-Max) | 6.8 (4.3, 23.0) | 2.9 | 7.8 (3.1, 8.6) | 10.3 (6.4, 18.8) | 8.2 (2.9, 23.0)
Day 2
N | 2 | 1 | 0 | 0 | 3
Mean (SD) | 13.9 (10.8) | 8.8 | | | 12.2 (8.2)
95% CI of the Mean | 0.0, 111.1 | 0 | | | 0.0, 32.5
Median (Min-Max) | 13.9 (6.2, 21.5) | 8.8 | | | 8.8 (6.2, 21.5)
Day 3
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 17.9 | | | 14.2 | 16.1 (2.6)
95% CI of the Mean | 0 | | | 0 | 0.0, 39.6
Median (Min-Max) | 17.9 | | | 14.2 | 16.1 (14.2, 17.9)
Last Dosing Day
N | 3 | | 1 | 2 | 6
Mean (SD) | 12.9 (12.4) | | 13.4 | 7.6 (3.0) | 11.2 (8.4)
95% CI of the Mean | 0.0, 43.6 | | 0 | 0.0, 34.9 | 2.4, 20.0
Median (Min-Max) | 7.0 (4.6, 27.1) | | 13.4 | 7.6 (5.4, 9.7) | 8.4 (4.6, 27.1)
Change From Baseline to Last Dosing Day
N | | 0 | 1 | 2 | 6
Mean (SD) | 3.3 (11.2) | | −3.8 | −12.1 (11.0) | −3.0 (11.5)
95% CI of the Mean | −24.7, 31.2 | | 0 | −111.2, 87.0 | −15.1, 9.0
Median (Min-Max) | 0.6 (−6.4, 15.6) | | −3.8 | −12.1 (−19.9,−4.3) | −4.1 (−19.9, 15.6)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.1.2 Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Hematocrit (%) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 10 | 5 | 7 | 7 | 29
Mean (SD) | 36.3 (4.1) | 40.6 (3.7) | 48.4 (7.6) | 45.7 (10.3) | 42.2 (8.3)
95% CI of the Mean | 33.3, 39.3 | 36.0, 45.2 | 41.4, 55.5 | 36.2, 55.2 | 39.1, 45.4
Median (Min-Max) | 35.5 (31.0, 45.0) | 39.0 (37.5, 46.0) | 47.0 (36.0, 57.0) | 47.0 (26.0, 59.0) | 42.7 (26.0, 59.0)
Day 1
N | 4 | 2 | 3 | 5 | 14
Mean (SD) | 33.3 (4.0) | 35.4 (0.5) | 44.3 (9.0) | 48.6 (10.3) | 41.4 (9.8)
95% CI of the Mean | 26.8, 39.7 | 30.9, 39.8 | 22.1, 66.6 | 35.9, 61.3 | 35.7, 47.1
Median (Min-Max) | 32.0 (30.0, 39.0) | 35.4 (35.0, 35.7) | 49.0 (34.0, 50.0) | 51.0 (32.0, 59.0) | 37.4 (30.0, 59.0)
Day 2
N | 2 | 3 | 0 | 0 | 5
Mean (SD) | 28.5 (9.2) | 41.8 (7.9) | | | 36.5 (10.2)
95% CI of the Mean | 0.0, 111.1 | 22.2, 61.3 | | | 23.7, 49.2
Median (Min-Max) | 28.5 (22.0, 35.0) | 38.0 (36.5, 50.8) | | | 36.5 (22.0, 50.8)
Day 3
N | 2 | 0 | 0 | 1 | 3
Mean (SD) | 32.5 (6.4) | | | 24.0 | 29.7 (6.7)
95% CI of the Mean | 0.0, 89.7 | | | 0 | 13.1, 46.2
Median (Min-Max) | 32.5 (28.0, 37.0) | | | 24.0 | 28.0 (24.0, 37.0)
Last Dosing Day
N | 4 | | 1 | 2 | 8
Mean (SD) | 33.3 (5.0) | 37.2 | 40.0 | 47.0 (4.2) | 38.0 (7.1)
95% CI of the Mean | 25.3, 41.2 | | 0 | 8.9, 85.1 | 32.1, 43.9
Median (Min-Max) | 35.0 (26.0, 37.0) | 37.2 | 40.0 | 47.0 (44.0, 50.0) | 37.1 (26.0, 50.0)
Change From Baseline to Last Dosing Day
N | 4 | 1 | 1 | 2 | 8
Mean (SD) | −4.0 (6.1) | −5.5 | −4.0 | −6.0 (4.2) | −4.7 (4.4)
95% CI of the Mean | −13.6, 5.6 | 0 | 0 | −44.1, 32.1 | −8.4,−1.0
Median (Min-Max) | −4.5 (−10.0, 3.0) | −5.5 | −4.0 | −6.0 (−9.0, −3.0) | −4.8 (−10.0, 3.0)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.1.3 Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Platelet Count (10^3^/mm^3^) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 9 | 5 | 7 | 7 | 28
Mean (SD) | 204.7 (100.1) | 197.6 (129.1) | 281.3 (174.5) | 178.6 (90.6) | 216.0 (124.9)
95% CI of the Mean | 127.7, 281.6 | 37.3, 357.9 | 119.9, 442.6 | 94.8, 262.4 | 167.6, 264.5
Median (Min-Max) | 184.0 (46.0, 366.0) | 198.0 (58.0, 383.0) | 194.0 (138.0, 636.0) | 200.0 (37.0, 266.0) | 198.0 (37.0, 636.0)
Day 1
N | 3 | 1 | 3 | 5 | 12
Mean (SD) | 132.3 (18.2) | 16.0 | 210.0 (111.0) | 184.0 (130.8) | 163.6 (107.4)
95% CI of the Mean | 87.2, 177.5 | 0 | 0.0, 485.7 | 21.6, 346.4 | 95.3, 231.8
Median (Min-Max) | 138.0 (112.0, 147.0) | 16.0 | 172.0 (123.0, 335.0) | 167.0 (47.0, 339.0) | 142.5 (16.0, 339.0)
Day 2
N | 2 | 1 | 0 | 0 | 3
Mean (SD) | 99.5 (77.1) | 30.0 | | | 76.3 (67.7)
95% CI of the Mean | 0.0, 792.0 | 0 | | | 0.0, 244.5
Median (Min-Max) | 99.5 (45.0, 154.0) | 30.0 | | | 45.0 (30.0, 154.0)
Day 3
N | 2 | 0 | 0 | 1 | 3
Mean (SD) | 416.5 (118.1) | | | 262.0 | 365.0 (122.2)
95% CI of the Mean | 0.0, 1477.5 | | | 0 | 61.5, 668.5
Median (Min-Max) | 416.5 (333.0, 500.0) | | | 262.0 | 333.0 (262.0, 500.0)
Last Dosing Day
N | 3 | 1 | 1 | 2 | 7
Mean (SD) | 209.0 (66.2) | 136.0 | 705.0 | 81.0 (14.1) | 232.9 (219.5)
95% CI of the Mean | 44.7, 373.3 | 0 | 0 | 0.0, 208.1 | 29.9, 435.9
Median (Min-Max) | 226.0 (136.0, 265.0) | 136.0 | 705.0 | 81.0 (71.0, 91.0) | 136.0 (71.0, 705.0)
Change From Baseline to Last Dosing Day
N | 3 | 1 | 1 | 2 | 7
Mean (SD) | 31.0 (50.3) | 38.0 | 69.0 | 29.5 (34.6) | 37.0 (35.4)
95% CI of the Mean | −94.0, 156.0 | 0 | 0 | −281.8, 340.8 | 4.3, 69.7
Median (Min-Max) | 5.0 (−1.0, 89.0) | 38.0 | 69.0 | 29.5 (5.0, 54.0) | 38.0 (−1.0, 89.0)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.1.4 Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Neutrophils (%) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 9 | 3 | 7 | 7 | 26
Mean (SD) | 45.6 (23.1) | 44.3 (20.7) | 49.7 (11.7) | 50.1 (13.3) | 47.8 (16.9)
95% CI of the Mean | 27.8, 63.3 | 0.0, 95.9 | 38.9, 60.5 | 37.8, 62.4 | 40.9, 54.6
Median (Min-Max) | 41.0 (14.0, 78.0) | 48.0 (22.0, 63.0) | 52.0 (33.0, 62.0) | 48.0 (25.0, 67.0) | 48.0 (14.0, 78.0)
Day 1
N | 3 | 1 | 3 | 5 | 12
Mean (SD) | 54.7 (29.0) | 40.0 | 64.3 (15.0) | 55.2 (19.3) | 56.1 (19.3)
95% CI of the Mean | 0.0, 126.8 | 0 | 27.0, 101.7 | 31.3, 79.1 | 43.8, 68.3
Median (Min-Max) | 61.0 (23.0, 80.0) | 40.0 | 63.0 (50.0, 80.0) | 64.0 (26.0, 74.0) | 62.0 (23.0, 80.0)
Day 2
N | 1 | 1 | 0 | 0 | 2
Mean (SD) | 49.0 | 60.0 | | | 54.5 (7.8)
95% CI of the Mean | 0 | 0 | | | 0.0, 124.4
Median (Min-Max) | 49.0 | 60.0 | | | 54.5 (49.0, 60.0)
Day 3
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 61.0 | | | 40.0 | 50.5 (14.8)
95% CI of the Mean | 0 | | | 0 | 0.0, 183.9
Median (Min-Max) | 61.0 | | | 40.0 | 50.5 (40.0, 61.0)
Last Dosing Day
N | 3 | 0 | 1 | 1 | 5
Mean (SD) | 42.3 (9.3) | | 23.0 | 42.0 | 38.4 (10.8)
95% CI of the Mean | 19.3, 65.4 | | 0 | 0 | 25.0, 51.8
Median (Min-Max) | 38.0 (36.0, 53.0) | | 23.0 | 42.0 | 38.0 (23.0, 53.0)
Change From Baseline to Last Dosing Day
N | 3 | 0 | 1 | 1 | 5
Mean (SD) | −0.7 (21.1) | | −16.0 | 17.0 | −0.2 (18.9)
95% CI of the Mean | −53.0, 51.7 | | 0 | 0 | −23.7, 23.3
Median (Min-Max) | 11.0 (−25.0, 12.0) | | −16.0 | 17.0 | 11.0 (−25.0, 17.0)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.1.5 Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Lymphocytes (%) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 9 | 3 | 7 | 7 | 26
Mean (SD) | 31.7 (18.3) | 28.0 (17.0) | 35.6 (9.9) | 35.4 (14.3) | 33.3 (14.5)
95% CI of the Mean | 17.6, 45.7 | 0.0, 70.2 | 26.4, 44.7 | 22.2, 48.7 | 27.5, 39.2
Median (Min-Max) | 32.0 (7.0, 59.0) | 28.0 (11.0, 45.0) | 32.0 (23.0, 50.0) | 32.0 (17.0, 61.0) | 32.0 (7.0, 61.0)
Day 1
N | 3 | 1 | 3 | 5 | 12
Mean (SD) | 26.7 (29.7) | 19.0 | 28.7 (12.6) | 25.0 (13.8) | 25.8 (16.3)
95% CI of the Mean | 0.0, 100.5 | 0 | 0.0, 59.9 | 7.9, 42.1 | 15.5, 36.2
Median (Min-Max) | 17.0 (3.0, 60.0) | 19.0 | 27.0 (17.0, 42.0) | 23.0 (10.0, 42.0) | 21.0 (3.0, 60.0)
Day 2
N | 1 | 1 | 0 | 0 | 2
Mean (SD) | 37.0 | 15.0 | | | 26.0 (15.6)
95% CI of the Mean | 0 | 0 | | | 0.0, 165.8
Median (Min-Max) | 37.0 | 15.0 | | | 26.0 (15.0, 37.0)
Day 3
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 28.0 | | | 36.0 | 32.0 (5.7)
95% CI of the Mean | 0 | | | 0 | 0.0, 82.8
Median (Min-Max) | 28.0 | | | 36.0 | 32.0 (28.0, 36.0)
Last Dosing Day
N | 3 | 0 | 1 | 1 | 5
| 0 | 0 | 0 | 0 | 0
Mean (SD) | 41.0 (7.8) | | 54.0 | 29.0 | 41.2 (10.4)
95% CI of the Mean | 21.6, 60.4 | | 0 | 0 | 28.3, 54.1
Median (Min-Max) | 45.0 (32.0, 46.0) | | 54.0 | 29.0 | 45.0 (29.0, 54.0)
Change From Baseline to Last Dosing Day
N | 3 | 0 | 1 | 1 | 5
Mean (SD) | 4.0 (20.8) | | 9.0 | −32.0 | −2.2 (22.3)
95% CI of the Mean | −47.7, 55.7 | | 0 | 0 | −29.9, 25.5
Median (Min-Max) | −7.0 (−9.0, 28.0) | | 9.0 | −32.0 | −7.0 (−32.0, 28.0)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.1.6 Summary of Clinical Laboratory Hematology Measurement by Visit and GA/PNA Group Test: Bands (%) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 9 | 3 | 6 | 7 | 25
Mean (SD) | 3.2 (4.4) | 15.0 (19.9) | 5.8 (4.8) | 3.4 (3.2) | 5.3 (7.8)
95% CI of the Mean | 0.0, 6.6 | 0.0, 64.5 | 0.8, 10.9 | 0.5, 6.4 | 2.1, 8.6
Median (Min-Max) | 2.0 (1.0, 15.0) | 4.0 (3.0, 38.0) | 5.0 (2.0, 15.0) | 2.0 (0.0, 8.0) | 2.0 (0.0, 38.0)
Day 1
N | 3 | 1 | 3 | 4 | 11
Mean (SD) | 4.3 (2.1) | 24.0 | 1.7 (1.2) | 10.5 (13.3) | 7.6 (9.9)
95% CI of the Mean | 0.0, 9.5 | 0 | 0.0, 4.5 | 0.0, 31.7 | 1.0, 14.3
Median (Min-Max) | 5.0 (2.0, 6.0) | 24.0 | 1.0 (1.0, 3.0) | 6.0 (0.0, 30.0) | 5.0 (0.0, 30.0)
Day 2
N | 0 | 0 | 0 | 0 | 0
Mean (SD)
95% CI of the Mean
Median (Min-Max)
Day 3
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 2.0 | | | 0.0 | 1.0 (1.4)
95% CI of the Mean | 0 | | | 0 | 0.0, 13.7
Median (Min-Max) | 2.0 | | | 0.0 | 1.0 (0.0, 2.0)
Last Dosing Day
N | 1 | 0 | 1 | 1 | 3
Mean (SD) | 3.0 | | 0.0 | 11.0 | 4.7 (5.7)
95% CI of the Mean | 0 | | 0 | 0 | 0.0, 18.8
Median (Min-Max) | 3.0 | | 0.0 | 11.0 | 3.0 (0.0, 11.0)
Change From Baseline to Last Dosing Day
N | 1 | 0 | 1 | 1 | 3
Mean (SD) | 1.0 | | −2.0 | 3.0 | 0.7 (2.5)
95% CI of the Mean | 0 | | 0 | 0 | −5.6, 6.9
Median (Min-Max) | 1.0 | | −2.0 | 3.0 | 1.0 (−2.0, 3.0)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.1 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Creatinine (mg/dL) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 10 | 3 | 7 | 6 | 26
Mean (SD) | 1.1 (0.4) | 1.1 (0.6) | 0.8 (0.3) | 0.8 (0.4) | 1.0 (0.4)
95% CI of the Mean | 0.8, 1.4 | 0.0, 2.6 | 0.5, 1.1 | 0.4, 1.2 | 0.8, 1.1
Median (Min-Max) | 1.2 (0.4, 1.5) | 0.8 (0.8, 1.8) | 0.8 (0.5, 1.4) | 0.8 (0.3, 1.3) | 0.9 (0.3, 1.8)
Day 1
N | 6 | 3 | 5 | 5 | 19
Mean (SD) | 1.3 (0.3) | 0.9 (0.1) | 0.8 (0.3) | 0.7 (0.2) | 1.0 (0.3)
95% CI of the Mean | 1.0, 1.6 | 0.7, 1.1 | 0.5, 1.2 | 0.6, 0.9 | 0.8, 1.1
Median (Min-Max) | 1.3 (0.9, 1.7) | 0.9 (0.8, 1.0) | 1.0 (0.5, 1.1) | 0.7 (0.6, 1.0) | 1.0 (0.5, 1.7)
Day 2
N | 6 | 3 | 4 | 0 | 13
Mean (SD) | 1.1 (0.5) | 0.8 (0.1) | 0.8 (0.3) | | 0.9 (0.4)
95% CI of the Mean | 0.6, 1.6 | 0.5, 1.1 | 0.4, 1.2 | | 0.7, 1.2
Median (Min-Max) | 1.1 (0.4, 1.9) | 0.9 (0.7, 0.9) | 0.8 (0.5, 1.0) | | 0.9 (0.4, 1.9)
Day 3
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 1.8 | | | 0.8 | 1.3 (0.7)
95% CI of the Mean | | | | | 0.0, 7.7
Median (Min-Max) | 1.8 | | | 0.8 | 1.3 (0.8, 1.8)
Last Dosing Day
N | 7 | 2 | 2 | 4 | 15
Mean (SD) | 1.4 (0.4) | 0.7 (0.3) | 0.8 (0.3) | 0.6 (0.2) | 1.0 (0.5)
95% CI of the Mean | 1.1, 1.8 | 0.0, 3.2 | 0.0, 3.3 | 0.3, 0.9 | 0.8, 1.3
Median (Min-Max) | 1.2 (1.0, 2.1) | 0.7 (0.5, 0.9) | 0.8 (0.6, 1.0) | 0.6 (0.4, 0.8) | 1.0 (0.4, 2.1)
Change From Baseline to Last Dosing Day
N | 7 | 1 | 1 | 3 | 12
Mean (SD) | 0.2 (0.4) | −0.3 | −0.8 | −0.2 (0.3) | −0.1 (0.4)
95% CI of the Mean | −0.2, 0.5 | | | −1.0, 0.6 | −0.3, 0.2
Median (Min-Max) | 0.1 (−0.3, 0.7) | −0.3 | −0.8 | −0.1 (−0.6, 0.0) | −0.1 (−0.8, 0.7)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.2 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: BUN(Urea) (mg/dL) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 10 | 3 | 7 | 6 | 26
Mean (SD) | 30.0 (17.6) | 29.7 (12.7) | 11.9 (6.5) | 9.7 (9.8) | 20.4 (15.8)
95% CI of the Mean | 17.4, 42.6 | 0.0, 61.1 | 5.9, 17.8 | 0.0, 19.9 | 14.0, 26.8
Median (Min-Max) | 28.0 (5.0, 58.0) | 25.0 (20.0, 44.0) | 11.0 (4.0, 21.0) | 7.0 (2.0, 28.0) | 17.0 (2.0, 58.0)
Day 1
N | 6 | 3 | 5 | 5 | 19
Mean (SD) | 43.3 (19.2) | 21.7 (12.3) | 8.8 (4.8) | 10.4 (7.0) | 22.2 (19.3)
95% CI of the Mean | 23.2, 63.5 | 0.0, 52.3 | 2.8, 14.8 | 1.7, 19.1 | 12.8, 31.5
Median (Min-Max) | 42.0 (17.0, 68.0) | 25.0 (8.0, 32.0) | 10.0 (3.0, 15.0) | 7.0 (5.0, 22.0) | 15.0 (3.0, 68.0)
Day 2
N | 6 | 3 | 4 | 0 | 13
Mean (SD) | 37.0 (25.6) | 23.3 (3.5) | 11.8 (2.9) | | 26.1 (20.2)
95% CI of the Mean | 10.2, 63.8 | 14.6, 32.1 | 7.2, 16.3 | | 13.9, 38.3
Median (Min-Max) | 32.0 (7.0, 72.0) | 23.0 (20.0, 27.0) | 10.5 (10.0, 16.0) | | 20.0 (7.0, 72.0)
Day 3
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 82.0 | | | 5.0 | 43.5 (54.4)
95% CI of the Mean | | | | | 0.0, 532.7
Median (Min-Max) | 82.0 | | | 5.0 | 43.5 (5.0, 82.0)
Last Dosing Day
N | 7 | 2 | 2 | 3 | 14
Mean (SD) | 51.1 (33.4) | 20.5 (0.7) | 6.5 (0.7) | 14.3 (10.7) | 32.5 (30.4)
95% CI of the Mean | 20.3, 82.0 | 14.1, 26.9 | 0.1, 12.9 | 0.0, 40.9 | 15.0, 50.0
Median (Min-Max) | 38.0 (17.0, 93.0) | 20.5 (20.0, 21.0) | 6.5 (6.0, 7.0) | 12.0 (5.0, 26.0) | 21.0 (5.0, 93.0)
Change From Baseline to Last Dosing Day
N | 7 | 1 | 1 | 2 | 11
Mean (SD) | 19.4 (29.1) | −23.0 | −14.0 | −1.0 (1.4) | 8.8 (27.5)
95% CI of the Mean | −7.4, 46.3 | | | −13.7, 11.7 | −9.7, 27.3
Median (Min-Max) | 5.0 (−10.0, 72.0) | −23.0 | −14.0 | −1.0 (−2.0, 0.0) | 0.0 (−23.0, 72.0)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.3 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: AST(SGOT) (U/L) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 2 | 1 | 0 | 3 | 6
Mean (SD) | 434.5 (597.5) | 25.0 | | 1521.7 (2479.1) | 909.8 (1732.4)
95% CI of the Mean | 0.0, 5802.9 | | | 0.0, 7680.1 | 0.0, 2727.9
Median (Min-Max) | 434.5 (12.0, 857.0) | 25.0 | | 165.0 (17.0, 4383.0) | 95.0 (12.0, 4383.0)
Day 1
N | 0 | 1 | 0 | 1 | 2
Mean (SD) | | 21.0 | | 32.0 | 26.5 (7.8)
95% CI of the Mean | | | | | 0.0, 96.4
Median (Min-Max) | | 21.0 | | 32.0 | 26.5 (21.0, 32.0)
Day 2
N | 0 | 2 | 0 | 1 | 3
Mean (SD) | | 15.0 (0.0) | | 2352.0 | 794.0 (1349.3)
95% CI of the Mean | | .,. | | | 0.0, 4145.8
Median (Min-Max) | | 15.0 (15.0, 15.0) | | 2352.0 | 15.0 (15.0, 2352.0)
Day 3
N | 0 | 0 | 0 | 0 | 0
Mean (SD)
95% CI of the Mean
Median (Min-Max)
Last Dosing Day
N | 0 | 1 | 0 | 1 | 2
Mean (SD) | | 17.0 | | 36.0 | 26.5 (13.4)
95% CI of the Mean | | | | | 0.0, 147.2
Median (Min-Max) | | 17.0 | | 36.0 | 26.5 (17.0, 36.0)
Change From Baseline to Last Dosing Day
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | −129.0 | −129.0
95% CI of the Mean
Median (Min-Max) | | | | −129.0 | −129.0

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.4 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: ALT(SGPT) (U/L) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 2 | 1 | 0 | 3 | 6
Mean (SD) | 165.5 (227.0) | 12.0 | | 359.0 (520.6) | 236.7 (373.9)
95% CI of the Mean | 0.0, 2204.8 | | | 0.0, 1652.2 | 0.0, 629.1
Median (Min-Max) | 165.5 (5.0, 326.0) | 12.0 | | 113.0 (7.0, 957.0) | 62.5 (5.0, 957.0)
Day 1
N | 0 | 1 | 0 | 1 | 2
Mean (SD) | | 7.0 | | 11.0 | 9.0 (2.8)
95% CI of the Mean | | | | | 0.0, 34.4
Median (Min-Max) | | 7.0 | | 11.0 | 9.0 (7.0, 11.0)
Day 2
N | 0 | 2 | 0 | 1 | 3
Mean (SD) | | 7.0 (1.4) | | 721.0 | 245.0 (412.2)
95% CI of the Mean | | 0.0, 19.7 | | | 0.0, 1269.0
Median (Min-Max) | | 7.0 (6.0, 8.0) | | 721.0 | 8.0 (6.0, 721.0)
Day 3
N | 0 | 0 | 0 | 0 | 0
Mean (SD)
95% CI of the Mean
Median (Min-Max)
Last Dosing Day
N | 0 | 1 | 0 | 1 | 2
Mean (SD) | | 6.0 | | 51.0 | 28.5 (31.8)
95% CI of the Mean | | | | | 0.0, 314.4
Median (Min-Max) | | 6.0 | | 51.0 | 28.5 (6.0, 51.0)
Change From Baseline to Last Dosing Day
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | −62.0 | −62.0
95% CI of the Mean
Median (Min-Max) | | | | −62.0 | −62.0

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.5 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Alkaline Phosphatase (U/L) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 2 | 1 | 0 | 3 | 6
Mean (SD) | 178.0 (82.0) | 208.0 | | 118.3 (29.5) | 153.2 (57.2)
95% CI of the Mean | 0.0, 915.0 | | | 45.0, 191.7 | 93.2, 213.2
Median (Min-Max) | 178.0 (120.0, 236.0) | 208.0 | | 120.0 (88.0, 147.0) | 133.5 (88.0, 236.0)
Day 1
N | 0 | 1 | 0 | 1 | 2
Mean (SD) | | 481.0 | | 161.0 | 321.0 (226.3)
95% CI of the Mean | | | | | 0.0, 2354.0
Median (Min-Max) | | 481.0 | | 161.0 | 321.0 (161.0, 481.0)
Day 2
N | 0 | 2 | 0 | 1 | 3
Mean (SD) | | 289.0 (135.8) | | 159.0 | 245.7 (121.9)
95% CI of the Mean | | 0.0, 1508.8 | | | 0.0, 548.4
Median (Min-Max) | | 289.0 (193.0, 385.0) | | 159.0 | 193.0 (159.0, 385.0)
Day 3
N | 0 | 0 | 0 | 0 | 0
Mean (SD)
95% CI of the Mean
Median (Min-Max)
Last Dosing Day
N | 0 | 1 | 0 | 1 | 2
Mean (SD) | | 275.0 | | 73.0 | 174.0 (142.8)
95% CI of the Mean | | | | | 0.0, 1457.3
Median (Min-Max) | | 275.0 | | 73.0 | 174.0 (73.0, 275.0)
Change From Baseline to Last Dosing Day
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | −15.0 | −15.0
95% CI of the Mean
Median (Min-Max) | | | | −15.0 | −15.0

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.6 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Total Bilirubin (mg/dL) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 10 | 2 | 7 | 7 | 26
Mean (SD) | 4.9 (2.4) | 3.8 (1.8) | 7.4 (3.6) | 6.6 (2.8) | 5.9 (3.0)
95% CI of the Mean | 3.1, 6.6 | 0.0, 19.6 | 4.1, 10.7 | 3.9, 9.2 | 4.7, 7.1
Median (Min-Max) | 4.6 (1.8, 10.4) | 3.8 (2.5, 5.0) | 7.3 (2.4, 12.8) | 6.9 (1.4, 10.3) | 5.5 (1.4, 12.8)
Day 1
N | 6 | 3 | 7 | 2 | 18
Mean (SD) | 5.2 (2.3) | 2.5 (1.5) | 6.4 (1.7) | 5.6 (1.1) | 5.2 (2.2)
95% CI of the Mean | 2.7, 7.6 | 0.0, 6.2 | 4.8, 8.0 | 0.0, 15.8 | 4.1, 6.3
Median (Min-Max) | 4.7 (2.9, 9.1) | 3.3 (0.8, 3.4) | 6.9 (3.0, 8.2) | 5.6 (4.8, 6.4) | 5.3 (0.8, 9.1)
Day 2
N | 5 | 2 | 5 | 2 | 14
Mean (SD) | 4.6 (2.0) | 3.0 (1.0) | 7.5 (2.6) | 4.5 (2.8) | 5.4 (2.6)
95% CI of the Mean | 2.2, 7.1 | 0.0, 11.9 | 4.2, 10.7 | 0.0, 29.9 | 3.9, 6.9
Median (Min-Max) | 3.7 (2.7, 7.0) | 3.0 (2.3, 3.7) | 7.1 (4.2, 11.3) | 4.5 (2.5, 6.5) | 5.4 (2.3, 11.3)
Day 3
N | 1 | 0 | 2 | 0 | 3
Mean (SD) | 5.1 | | 7.4 (0.4) | | 6.6 (1.3)
95% CI of the Mean | | | 4.2, 10.5 | | 3.3, 9.9
Median (Min-Max) | 5.1 | | 7.4 (7.1, 7.6) | | 7.1 (5.1, 7.6)
Last Dosing Day
N | 8 | 1 | 2 | 2 | 13
Mean (SD) | 3.9 (0.9) | 1.3 | 6.9 (5.9) | 4.4 (3.1) | 4.2 (2.5)
95% CI of the Mean | 3.1, 4.7 | | 0.0, 60.3 | 0.0, 32.4 | 2.7, 5.8
Median (Min-Max) | 3.9 (2.1, 5.1) | 1.3 | 6.9 (2.7, 11.1) | 4.4 (2.2, 6.6) | 3.8 (1.3, 11.1)
Change From Baseline to Last Dosing Day
N | 8 | 0 | 1 | 2 | 11
Mean (SD) | −0.4 (1.8) | | 7.3 | −3.0 (4.9) | −0.1 (3.5)
95% CI of the Mean | −1.9, 1.2 | | | −47.5, 41.5 | −2.5, 2.2
Median (Min-Max) | −0.1 (−3.4, 1.7) | | 7.3 | −3.0 (−6.5, 0.5) | 0.0 (−6.5, 7.3)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.7 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Direct Bilirubin (mg/dL) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 10 | 2 | 7 | 6 | 25
Mean (SD) | 0.6 (1.0) | 0.4 (0.1) | 0.4 (0.1) | 0.4 (0.1) | 0.5 (0.6)
95% CI of the Mean | 0.0, 1.3 | 0.0, 1.0 | 0.3, 0.4 | 0.3, 0.6 | 0.2, 0.7
Median (Min-Max) | 0.3 (0.2, 3.3) | 0.4 (0.3, 0.4) | 0.3 (0.3, 0.5) | 0.5 (0.3, 0.6) | 0.3 (0.2, 3.3)
Day 1
N | 6 | 2 | 7 | 1 | 16
Mean (SD) | 0.7 (1.1) | 0.3 (0.1) | 0.4 (0.1) | 0.2 | 0.5 (0.7)
95% CI of the Mean | 0.0, 1.8 | 0.0, 0.9 | 0.3, 0.6 | | 0.2, 0.8
Median (Min-Max) | 0.3 (0.2, 2.9) | 0.3 (0.2, 0.3) | 0.4 (0.3, 0.7) | 0.2 | 0.3 (0.2, 2.9)
Day 2
N | 5 | 2 | 5 | 2 | 14
Mean (SD) | 0.3 (0.2) | 0.5 (0.1) | 0.4 (0.1) | 0.8 (0.6) | 0.4 (0.3)
95% CI of the Mean | 0.1, 0.6 | 0.0, 1.8 | 0.2, 0.6 | 0.0, 5.9 | 0.3, 0.6
Median (Min-Max) | 0.2 (0.2, 0.7) | 0.5 (0.4, 0.6) | 0.4 (0.3, 0.6) | 0.8 (0.4, 1.2) | 0.4 (0.2, 1.2)
Day 3
N | 1 | 0 | 2 | 0 | 3
Mean (SD) | 0.3 | | 0.5 (0.1) | | 0.4 (0.1)
95% CI of the Mean | | | 0.0, 1.1 | | 0.2, 0.6
Median (Min-Max) | 0.3 | | 0.5 (0.4, 0.5) | | 0.4 (0.3, 0.5)
Last Dosing Day
N | 8 | 1 | 2 | 1 | 12
Mean (SD) | 0.3 (0.1) | 0.4 | 0.5 (0.1) | 0.4 | 0.4 (0.1)
95% CI of the Mean | 0.3, 0.4 | | 0.0, 1.8 | | 0.3, 0.4
Median (Min-Max) | 0.3 (0.2, 0.5) | 0.4 | 0.5 (0.4, 0.6) | 0.4 | 0.4 (0.2, 0.6)
Change From Baseline to Last Dosing Day
N | 8 | 0 | 1 | 1 | 10
Mean (SD) | 0.0 (0.1) | | 0.1 | −0.2 | 0.0 (0.1)
95% CI of the Mean | −0.1, 0.1 | | | | −0.1, 0.1
Median (Min-Max) | 0.1 (−0.1, 0.2) | | 0.1 | −0.2 | 0.1 (−0.2, 0.2)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.8 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Sodium (mmol/L) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 10 | 4 | 7 | 6 | 27
Mean (SD) | 139.3 (5.8) | 140.3 (7.4) | 138.9 (3.5) | 136.5 (3.0) | 138.7 (4.9)
95% CI of the Mean | 135.2, 143.4 | 128.5, 152.0 | 135.6, 142.1 | 133.3, 139.7 | 136.8, 140.6
Median (Min-Max) | 142.0 (130.0, 145.0) | 138.5 (134.0, 150.0) | 139.0 (133.0, 144.0) | 136.0 (133.0, 142.0) | 139.0 (130.0, 150.0)
Day 1
N | 7 | 5 | 5 | 5 | 22
Mean (SD) | 139.1 (7.5) | 140.8 (9.3) | 141.0 (5.6) | 132.8 (4.4) | 138.5 (7.3)
95% CI of the Mean | 132.2, 146.1 | 129.3, 152.3 | 134.1, 147.9 | 127.3, 138.3 | 135.3, 141.7
Median (Min-Max) | 144.0 (127.0, 146.0) | 141.0 (131.0, 151.0) | 144.0 (134.0, 146.0) | 133.0 (126.0, 138.0) | 137.0 (126.0, 151.0)
Day 2
N | 7 | 3 | 4 | 0 | 14
Mean (SD) | 138.7 (5.7) | 143.3 (9.0) | 142.5 (3.3) | | 140.8 (5.9)
95% CI of the Mean | 133.4, 144.0 | 120.9, 165.7 | 137.2, 147.8 | | 137.4, 144.2
Median (Min-Max) | 137.0 (131.0, 146.0) | 144.0 (134.0, 152.0) | 143.5 (138.0, 145.0) | | 142.0 (131.0, 152.0)
Day 3
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 145.0 | | | 139.0 | 142.0 (4.2)
95% CI of the Mean | | | | | 103.9, 180.1
Median (Min-Max) | 145.0 | | | 139.0 | 142.0 (139.0, 145.0)
Last Dosing Day
N | 7 | 4 | 2 | 4 | 17
Mean (SD) | 139.6 (4.9) | 141.5 (9.4) | 136.5 (0.7) | 138.5 (3.9) | 139.4 (5.6)
95% CI of the Mean | 135.0, 144.1 | 126.5, 156.5 | 130.1, 142.9 | 132.3, 144.7 | 136.6, 142.3
Median (Min-Max) | 137.0 (136.0, 150.0) | 144.0 (128.0, 150.0) | 136.5 (136.0, 137.0) | 138.5 (134.0, 143.0) | 137.0 (128.0, 150.0)
Change From Baseline to Last Dosing Day
N | 7 | 3 | 1 | 3 | 14
Mean (SD) | −2.3 (5.7) | −1.0 (9.5) | −1.0 | 4.0 (3.0) | −0.6 (6.1)
95% CI of the Mean | −7.6, 3.0 | −24.7, 22.7 | | −3.5, 11.5 | −4.1, 2.9
Median (Min-Max) | −3.0 (−8.0, 7.0) | −6.0 (−7.0, 10.0) | −1.0 | 4.0 (1.0, 7.0) | −1.0 (−8.0, 10.0)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.9 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Potassium (mmol/L) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 10 | 4 | 6 | 5 | 25
Mean (SD) | 4.7 (1.0) | 4.6 (0.4) | 4.2 (1.2) | 4.3 (0.9) | 4.5 (0.9)
95% CI of the Mean | 4.0, 5.4 | 4.0, 5.1 | 2.9, 5.4 | 3.3, 5.4 | 4.1, 4.8
Median (Min-Max) | 4.2 (3.7, 5.9) | 4.6 (4.1, 4.9) | 3.5 (3.3, 5.9) | 4.1 (3.3, 5.6) | 4.2 (3.3, 5.9)
Day 1
N | 7 | 5 | 4 | 5 | 21
Mean (SD) | 4.6 (1.3) | 4.7 (0.8) | 4.6 (1.3) | 4.1 (1.5) | 4.5 (1.2)
95% CI of the Mean | 3.4, 5.8 | 3.7, 5.6 | 2.4, 6.7 | 2.2, 6.0 | 3.9, 5.0
Median (Min-Max) | 4.1 (3.3, 6.8) | 4.6 (3.8, 5.9) | 4.9 (2.8, 5.7) | 3.5 (2.8, 6.7) | 4.2 (2.8, 6.8)
Day 2
N | 7 | 3 | 4 | 0 | 14
Mean (SD) | 4.3 (0.7) | 4.0 (0.7) | 4.0 (1.2) | | 4.1 (0.8)
95% CI of the Mean | 3.6, 4.9 | 2.3, 5.6 | 2.1, 5.9 | | 3.7, 4.6
Median (Min-Max) | 4.0 (3.5, 5.7) | 4.3 (3.2, 4.4) | 4.2 (2.6, 5.2) | | 4.2 (2.6, 5.7)
Day 3
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 5.1 | | | 4.3 | 4.7 (0.6)
95% CI of the Mean | | | | | 0.0, 9.8
Median (Min-Max) | 5.1 | | | 4.3 | 4.7 (4.3, 5.1)
Last Dosing Day
N | 7 | 4 | 2 | 4 | 17
Mean (SD) | 4.7 (0.8) | 4.9 (0.8) | 4.0 (1.0) | 4.1 (1.3) | 4.5 (0.9)
95% CI of the Mean | 4.0, 5.5 | 3.5, 6.2 | 0.0, 12.9 | 2.1, 6.2 | 4.1, 5.0
Median (Min-Max) | 4.5 (3.8, 5.6) | 4.6 (4.2, 6.1) | 4.0 (3.3, 4.7) | 3.7 (3.2, 6.0) | 4.5 (3.2, 6.1)
Change From Baseline to Last Dosing Day
N | 7 | 3 | 1 | 3 | 14
Mean (SD) | −0.3 (1.1) | −0.1 (0.2) | 0.0 | −0.5 (1.1) | −0.3 (0.9)
95% CI of the Mean | −1.3, 0.7 | −0.7, 0.4 | | −3.1, 2.2 | −0.8, 0.2
Median (Min-Max) | −0.3 (−1.8, 1.7) | −0.2 (−0.3, 0.1) | 0.0 | −0.7 (−1.4, 0.7) | −0.3 (−1.8, 1.7)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.10 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Calcium (mg/dL) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 9 | 1 | 7 | 6 | 23
Mean (SD) | 9.3 (0.7) | 8.7 | 9.1 (1.1) | 9.2 (0.5) | 9.2 (0.8)
95% CI of the Mean | 8.7, 9.9 | | 8.1, 10.0 | 8.7, 9.7 | 8.9, 9.5
Median (Min-Max) | 9.4 (8.2, 10.3) | 8.7 | 9.1 (7.9, 11.0) | 9.1 (8.8, 10.0) | 9.2 (7.9, 11.0)
Day 1
N | 6 | 2 | 5 | 5 | 18
Mean (SD) | 9.3 (1.1) | 8.1 (0.6) | 8.8 (0.5) | 9.3 (1.0) | 9.0 (0.9)
95% CI of the Mean | 8.2, 10.4 | 2.3, 13.8 | 8.2, 9.4 | 8.1, 10.6 | 8.6, 9.5
Median (Min-Max) | 9.4 (7.8, 10.7) | 8.1 (7.6, 8.5) | 8.6 (8.5, 9.7) | 9.4 (8.1, 10.7) | 8.7 (7.6, 10.7)
Day 2
N | 6 | 3 | 4 | 0 | 13
Mean (SD) | 9.6 (1.0) | 9.1 (0.9) | 9.2 (0.6) | | 9.3 (0.8)
95% CI of the Mean | 8.6, 10.6 | 6.8, 11.4 | 8.3, 10.1 | | 8.8, 9.8
Median (Min-Max) | 9.9 (8.4, 10.9) | 9.5 (8.0, 9.7) | 9.3 (8.4, 9.8) | | 9.5 (8.0, 10.9)
Day 3
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 9.4 | | | 9.7 | 9.6 (0.2)
95% CI of the Mean | | | | | 7.6, 11.5
Median (Min-Max) | 9.4 | | | 9.7 | 9.6 (9.4, 9.7)
Last Dosing Day
N | 7 | 2 | 2 | 4 | 15
Mean (SD) | 10.4 (0.6) | 8.8 (0.1) | 9.0 (0.5) | 9.5 (0.4) | 9.8 (0.8)
95% CI of the Mean | 9.9, 11.0 | 7.5, 10.1 | 4.5, 13.4 | 8.8, 10.2 | 9.3, 10.2
Median (Min-Max) | 10.6 (9.5, 11.4) | 8.8 (8.7, 8.9) | 9.0 (8.6, 9.3) | 9.5 (9.1, 10.1) | 9.6 (8.6, 11.4)
Change From Baseline to Last Dosing Day
N | 7 | 1 | 1 | 3 | 12
Mean (SD) | 1.1 (0.8) | 0.0 | 1.2 | 0.4 (0.8) | 0.9 (0.8)
95% CI of the Mean | 0.4, 1.9 | | | −1.6, 2.4 | 0.4, 1.4
Median (Min-Max) | 1.2 (−0.2, 2.1) | 0.0 | 1.2 | 0.5 (−0.4, 1.2) | 1.0 (−0.4, 2.1)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.2.11 Summary of Clinical Laboratory Serum Chemistry Measurement by Visit and GA/PNA Group Test: Albumin (g/dL) Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Baseline
N | 1 | 0 | 0 | 1 | 2
Mean (SD) | 1.4 | | | 1.7 | 1.6 (0.2)
95% CI of the Mean | | | | | 0.0, 3.5
Median (Min-Max) | 1.4 | | | 1.7 | 1.6 (1.4, 1.7)
Day 1
N | 0 | 1 | 0 | 0 | 1
Mean (SD) | | 1.8 | | | 1.8
95% CI of the Mean
Median (Min-Max) | | 1.8 | | | 1.8
Day 2
N | 0 | 2 | 0 | 1 | 3
Mean (SD) | | 3.0 (0.1) | | 2.4 | 2.8 (0.3)
95% CI of the Mean | | 2.3, 3.6 | | | 2.0, 3.6
Median (Min-Max) | | 3.0 (2.9, 3.0) | | 2.4 | 2.9 (2.4, 3.0)
Day 3
N | 0 | 0 | 0 | 0 | 0
Mean (SD)
95% CI of the Mean
Median (Min-Max)
Last Dosing Day
N | 0 | 1 | 0 | 0 | 1
Mean (SD) | | 2.0 | | | 2.0
95% CI of the Mean
Median (Min-Max) | | 2.0 | | | 2.0
Change From Baseline to Last Dosing Day
N | 0 | 0 | 0 | 0 | 0
Mean (SD)
95% CI of the Mean
Median (Min-Max)

Note: Change is calculated by follow-up value minus baseline value.

Table 14.3.2.3.1.1 Summary of Post-baseline^1^ Serum Liver Biochemistries Worse-Grade Toxicities by GA and PNA Group Safety Population

Serum Liver Biochemistries | Age Strata | | | | Total; (N=32)
Serum Liver Biochemistries | GA 23-29 weeks; (N=10) | GA 30-34 weeks; (N=5) | GA 35-42 weeks; PNA <14 days; (N=9) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=32)
ALT
Grade 0^2^ | 0 | 4 (80.0%) | 0 | 3 (37.5%) | 7 (21.9%)
Grade 1 (1.25 to < 2.5 x ULN) | 0 | 0 | 0 | 0 | 0
Grade 2 (≥ 2.5 - < 5 x ULN) | 0 | 0 | 0 | 0 | 0
Grade 3 (≥ 5 - < 10 x ULN) | 0 | 0 | 0 | 0 | 0
Grade 4 (≥ 10 x ULN) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 10 (100.0%) | 1 (20.0%) | 9 (100.0%) | 5 (62.5%) | 25 (78.1%)
AST
Grade 0^2^ | 0 | 4 (80.0%) | 0 | 3 (37.5%) | 7 (21.9%)
Grade 1 (1.25 to < 2.5 x ULN) | 0 | 0 | 0 | 0 | 0
Grade 2 (≥ 2.5 - < 5 x ULN) | 0 | 0 | 0 | 0 | 0
Grade 3 (≥ 5 - < 10 x ULN) | 0 | 0 | 0 | 0 | 0
Grade 4 (≥ 10 x ULN) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 10 (100.0%) | 1 (20.0%) | 9 (100.0%) | 5 (62.5%) | 25 (78.1%)
Bilirubin (direct)
Grade 0^2^ | 9 (90.0%) | 4 (80.0%) | 8 (88.9%) | 3 (37.5%) | 24 (75.0%)
Grade 1 (1.1 to < 1.6 x ULN) | 0 | 0 | 0 | 0 | 0
Grade 2 (1.6 to < 2.6 x ULN) | 0 | 0 | 0 | 1 (12.5%) | 1 (3.1%)
Grade 3 (2.6 - 5.0 x ULN) | 0 | 0 | 0 | 0 | 0
Grade 4 (> 5.0 x ULN) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 1 (10.0%) | 1 (20.0%) | 1 (11.1%) | 4 (50.0%) | 7 (21.9%)

Note:

1 Baseline biochemistry is the lab value reported at baseline visit 00 or 00A.

2 Grade 0 includes participants with baseline value worse than the worst post-baseline value and post-baseline values within normal range.

ULN of ALT: 45 U/L, ULN of AST: 120 U/L, ULN of direct bilirubin: 0.7 mg/dL

Table 14.3.2.3.1.2 Summary of Post-baseline^1^ Serum Liver Biochemistries Worse-Grade Toxicities by Maximum Dose Group Safety Population

Serum Liver Biochemistries | Maximum Daily Dose | | | Total; (N=32)
Serum Liver Biochemistries | <50 mg/kg; (N=2) | 50-70 mg/kg; (N=13) | >70 mg/kg; (N=17) | Total; (N=32)
ALT
Grade 0^2^ | 0 | 5 (38.5%) | 2 (11.8%) | 7 (21.9%)
Grade 1 (1.25 to < 2.5 x ULN) | 0 | 0 | 0 | 0
Grade 2 (≥ 2.5 - < 5 x ULN) | 0 | 0 | 0 | 0
Grade 3 (≥ 5 - < 10 x ULN) | 0 | 0 | 0 | 0
Grade 4 (≥ 10 x ULN) | 0 | 0 | 0 | 0
Missing post-baseline values | 2 (100.0%) | 8 (61.5%) | 15 (88.2%) | 25 (78.1%)
AST
Grade 0^2^ | 0 | 5 (38.5%) | 2 (11.8%) | 7 (21.9%)
Grade 1 (1.25 to < 2.5 x ULN) | 0 | 0 | 0 | 0
Grade 2 (≥ 2.5 - < 5 x ULN) | 0 | 0 | 0 | 0
Grade 3 (≥ 5 - < 10 x ULN) | 0 | 0 | 0 | 0
Grade 4 (≥ 10 x ULN) | 0 | 0 | 0 | 0
Missing post-baseline values | 2 (100.0%) | 8 (61.5%) | 15 (88.2%) | 25 (78.1%)
Bilirubin (direct)
Grade 0^2^ | 2 (100.0%) | 11 (84.6%) | 11 (64.7%) | 24 (75.0%)
Grade 1 (1.1 to < 1.6 x ULN) | 0 | 0 | 0 | 0
Grade 2 (1.6 to < 2.6 x ULN) | 0 | 0 | 1 (5.9%) | 1 (3.1%)
Grade 3 (2.6 - 5.0 x ULN) | 0 | 0 | 0 | 0
Grade 4 (> 5.0 x ULN) | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 2 (15.4%) | 5 (29.4%) | 7 (21.9%)

Note:

1 Baseline biochemistry is the lab value reported at baseline visit 00 or 00A.

2 Grade 0 includes participants with baseline value worse than the worst post-baseline value and post-baseline values within normal range.

ULN of ALT: 45 U/L, ULN of AST: 120 U/L, ULN of direct bilirubin: 0.7 mg/dL

Table 14.3.2.3.2.1 Summary of Post-baseline^1^ Serum Creatinine Worse-Grade Toxicities by GA and PNA Group Safety Population

Increased Serum Creatinine | Age Strata | | | | Total; (N=32)
Increased Serum Creatinine | GA 23-29 weeks; (N=10) | GA 30-34 weeks; (N=5) | GA 35-42 weeks; PNA <14 days; (N=9) | GA 35-42 weeks; PNA>=14 days; (N=8) | Total; (N=32)
Grade 0^2^ | 4 (40.0%) | 2 (40.0%) | 3 (33.3%) | 4 (50.0%) | 13 (40.6%)
Grade 1 (1.1 to 1.3 x ULN) | 0 | 0 | 0 | 0 | 0
Grade 2 (> 1.3 to 1.8 x ULN OR Increase of > 0.3 mg/dL above baseline | 3 (30.0%) | 0 | 0 | 3 (37.5%) | 6 (18.8%)
Grade 3 (> 1.8 to < 3.5 x ULN OR Increase of 1.5 to < 2.0 x above baseline) | 2 (20.0%) | 3 (60.0%) | 3 (33.3%) | 0 | 8 (25.0%)
Grade 4 (> 3.5 x ULN OR Increase of > 2.0 x above baseline) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 1 (10.0%) | 0 | 3 (33.3%) | 1 (12.5%) | 5 (15.6%)

Note:

1 Baseline biochemistry is the lab value reported at baseline visit 00 or 00A.

2 Grade 0 includes participants with baseline creatinine value worse than the worst post-baseline value and post-baseline values within normal range.

ULN of creatinine: 0.4 mg/dL.

Table 14.3.2.3.2.2 Summary of Post-baseline^1^ Serum Creatinine Worse-Grade Toxicities by Maximum Dose Group Safety Population

Increased Serum Creatinine | Maximum Daily Dose | | | Total; (N=32)
Increased Serum Creatinine | <50 mg/kg; (N=2) | 50-70 mg/kg; (N=13) | >70 mg/kg; (N=17) | Total; (N=32)
Grade 0^2^ | 1 (50.0%) | 4 (30.8%) | 8 (47.1%) | 13 (40.6%)
Grade 1 (1.1 to 1.3 x ULN) | 0 | 0 | 0 | 0
Grade 2 (> 1.3 to 1.8 x ULN OR Increase of > 0.3 mg/dL above baseline | 0 | 4 (30.8%) | 2 (11.8%) | 6 (18.8%)
Grade 3 (> 1.8 to < 3.5 x ULN OR Increase of 1.5 to < 2.0 x above baseline) | 1 (50.0%) | 4 (30.8%) | 3 (17.6%) | 8 (25.0%)
Grade 4 (> 3.5 x ULN OR Increase of > 2.0 x above baseline) | 0 | 0 | 0 | 0
Missing post-baseline values | 0 | 1 (7.7%) | 4 (23.5%) | 5 (15.6%)

Note:

1 Baseline biochemistry is the lab value reported at baseline visit 00 or 00A.

2 Grade 0 includes participants with baseline creatinine value worse than the worst post-baseline value and post-baseline values within normal range.

ULN of creatinine: 0.4 mg/dL.

Table 14.3.2.3.3.1 Summary of Post-baseline^1^ Hematology Biochemistries Worse-Grade Toxicities by GA and PNA Group Safety Population

Hematology Biochemistries | Age Strata | | | | Total; (N=32)
Hematology Biochemistries | GA 23-29 weeks; (N=10) | GA 30-34 weeks; (N=5) | GA 35-42 weeks; PNA <14 days; (N=9) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=32)
WBC, Elevated
Grade 0^2^ | 6 (60.0%) | 1 (20.0%) | 4 (44.4%) | 6 (75.0%) | 17 (53.1%)
Grade 1 (≥30^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 2 (≥50^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 3 (≥75^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 4 (≥100^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 4 (40.0%) | 4 (80.0%) | 5 (55.6%) | 2 (25.0%) | 15 (46.9%)
WBC, Decreased
Grade 0^2^ | 6 (60.0%) | 1 (20.0%) | 4 (44.4%) | 6 (75.0%) | 17 (53.1%)
Grade 1 (. 2^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 2 (≤1.5^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 3 (≤1^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 4 (≤0.5^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 4 (40.0%) | 4 (80.0%) | 5 (55.6%) | 2 (25.0%) | 15 (46.9%)
Hematocrit, Elevated
Grade 0^2^ | 8 (80.0%) | 5 (100.0%) | 4 (44.4%) | 6 (75.0%) | 23 (71.9%)
Grade 1 (≥60%) | 0 | 0 | 0 | 0 | 0
Grade 2 (≥65%) | 0 | 0 | 0 | 0 | 0
Grade 3 (≥70%) | 0 | 0 | 0 | 0 | 0
Grade 4 (≥75%) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 2 (20.0%) | 0 | 5 (55.6%) | 2 (25.0%) | 9 (28.1%)
Hematocrit, Decreased
Grade 0^2^ | 2 (20.0%) | 2 (40.0%) | 3 (33.3%) | 5 (62.5%) | 12 (37.5%)
Grade 1^*^ | 0 | 3 (60.0%) | 0 | 0 | 3 (9.4%)
Grade 2^*^ | 3 (30.0%) | 0 | 1 (11.1%) | 0 | 4 (12.5%)
Grade 3^*^ | 1 (10.0%) | 0 | 0 | 1 (12.5%) | 2 (6.3%)
Grade 4^*^ | 2 (20.0%) | 0 | 0 | 0 | 2 (6.3%)
Missing post-baseline values | 2 (20.0%) | 0 | 5 (55.6%) | 2 (25.0%) | 9 (28.1%)
Platelets, Elevated
Grade 0^2^ | 5 (50.0%) | 2 (40.0%) | 3 (33.3%) | 4 (50.0%) | 14 (43.8%)
Grade 1 (≥400^*^10^9^/L) | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Grade 2 (≥500^*^10^9^/L) | 1 (10.0%) | 0 | 1 (11.1%) | 2 (25.0%) | 4 (12.5%)
Grade 3 (≥750^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 4 (≥1000^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Missing post-baseline values | 3 (30.0%) | 3 (60.0%) | 5 (55.6%) | 2 (25.0%) | 13 (40.6%)
Platelets, Decreased
Grade 0^2^ | 6 (60.0%) | 4 (80.0%) | 3 (33.3%) | 6 (75.0%) | 19 (59.4%)
Grade 1 (<125^*^10^9^/L) | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Grade 2 (<100^*^10^9^/L) | 0 | 0 | 0 | 0 | 0
Grade 3 (<50^*^10^9^/L) | 1 (10.0%) | 0 | 0 | 0 | 1 (3.1%)
Grade 4 (<25^*^10^9^/L) | 0 | 1 (20.0%) | 0 | 0 | 1 (3.1%)
Missing post-baseline values | 3 (30.0%) | 0 | 5 (55.6%) | 2 (25.0%) | 10 (31.3%)

Note:

1 Baseline biochemistry is the lab value reported at baseline visit 00 or 00A.

2 Grade 0 includes participants with baseline value worse than the worst post-baseline value and post-baseline values within normal range.

* Low HCT Grades are from DAIDS levels based on PNA under convention 3x HGB.

Table 14.3.2.3.3.2 Summary of Post-baseline^1^ Hematology Biochemistries Worse-Grade Toxicities by Maximum Dose Group Safety Population

Hematology Biochemistries | Maximum Daily Dose | | | Total; (N=32)
Hematology Biochemistries | <50 mg/kg; (N=2) | 50-70 mg/kg; (N=13) | >70 mg/kg; (N=17) | Total; (N=32)
WBC, Elevated
Grade 0^2^ | 0 | 6 (46.2%) | 11 (64.7%) | 17 (53.1%)
Grade 1 (≥30^*^10^9^/L) | 0 | 0 | 0 | 0
Grade 2 (≥50^*^10^9^/L) | 0 | 0 | 0 | 0
Grade 3 (≥75^*^10^9^/L) | 0 | 0 | 0 | 0
Grade 4 (≥100^*^10^9^/L) | 0 | 0 | 0 | 0
Missing post-baseline values | 2 (100.0%) | 7 (53.8%) | 6 (35.3%) | 15 (46.9%)
WBC, Decreased
Grade 0^2^ | 0 | 6 (46.2%) | 11 (64.7%) | 17 (53.1%)
Grade 1 (≤2^*^10^9^/L) | 0 | 0 | 0 | 0
Grade 2 (≤1.5^*^10^9^/L) | 0 | 0 | 0 | 0
Grade 3 (≤1^*^10^9^/L) | 0 | 0 | 0 | 0
Grade 4 (≤0.5^*^10^9^/L) | 0 | 0 | 0 | 0
Missing post-baseline values | 2 (100.0%) | 7 (53.8%) | 6 (35.3%) | 15 (46.9%)
Hematocrit, Elevated
Grade 0^2^ | 0 | 11 (84.6%) | 12 (70.6%) | 23 (71.9%)
Grade 1 (≥60%) | 0 | 0 | 0 | 0
Grade 2 (≥65%) | 0 | 0 | 0 | 0
Grade 3 (≥70%) | 0 | 0 | 0 | 0
Grade 4 (≥75%) | 0 | 0 | 0 | 0
Missing post-baseline values | 2 (100.0%) | 2 (15.4%) | 5 (29.4%) | 9 (28.1%)
Hematocrit, Decreased
Grade 0^2^ | 0 | 4 (30.8%) | 8 (47.1%) | 12 (37.5%)
Grade 1^*^ | 0 | 2 (15.4%) | 1 (5.9%) | 3 (9.4%)
Grade 2^*^ | 0 | 2 (15.4%) | 2 (11.8%) | 4 (12.5%)
Grade 3^*^ | | 1 (7.7%) | 1 (5.9%) | 2 (6.3%)
Grade 4^*^ | 0 | 2 (15.4%) | 0 | 2 (6.3%)
Missing post-baseline values | 2 (100.0%) | 2 (15.4%) | 5 (29.4%) | 9 (28.1%)
Platelets, Elevated
Grade 0^2^ | 0 | 6 (46.2%) | 8 (47.1%) | 14 (43.8%)
Grade 1 (≥400^*^10^9^/L) | 0 | 0 | 1 (5.9%) | 1 (3.1%)
Grade 2 (≥500^*^10^9^/L) | 0 | 2 (15.4%) | 2 (11.8%) | 4 (12.5%)
Grade 3 (≥750^*^10^9^/L) | 0 | 0 | 0 | 0
Grade 4 (≥1000^*^10^9^/L) | 0 | 0 | 0 | 0
Missing post-baseline values | 2 (100.0%) | 5 (38.5%) | 6 (35.3%) | 13 (40.6%)
Platelets, Decreased
Grade 0^2^ | 0 | 11 (84.6%) | 8 (47.1%) | 19 (59.4%)
Grade 1 (<125^*^10^9^/L) | 0 | 0 | 1 (5.9%) | 1 (3.1%)
Grade 2 (<100^*^10^9^/L) | 0 | 0 | 0 | 0
Grade 3 (<50^*^10^9^/L) | 0 | 0 | 1 (5.9%) | 1 (3.1%)
Grade 4 (<25^*^10^9^/L) | 0 | 0 | 1 (5.9%) | 1 (3.1%)
Missing post-baseline values | 2 (100.0%) | 2 (15.4%) | 6 (35.3%) | 10 (31.3%)

Note:

1 Baseline biochemistry is the lab value reported at baseline visit 00 or 00A.

2 Grade 0 includes participants with baseline value worse than the worst post-baseline value and post-baseline values within normal range.

* Low HCT Grades are from DAIDS levels based on PNA under convention 3x HGB.

Table 14.3.3 Summary of Actual Weight (grams) by Visit and GA/PNA Group Safety Population

| Age Strata | | | | Total; (N=32)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Actual Weight at Baseline
N | 10 | 5 | 9 | 8 | 32
Mean (SD) | 872 (323) | 864 (162) | 1725 (537) | 3165 (911) | 1684 (1088)
95% CI of the Mean | 641, 1103 | 663, 1066 | 1312, 2138 | 2404, 3926 | 1292, 2076
Median (Min-Max) | 810 (440, 1560) | 810 (703, 1100) | 1770 (800, 2645) | 3138 (2060, 4840) | 1400 (440, 4840)
Actual Weight at Day 1
N | 10 | 5 | 8 | 7 | 30
Mean (SD) | 875 (366) | 868 (170) | 1613 (443) | 3130 (987) | 1597 (1065)
95% CI of the Mean | 613, 1136 | 657, 1079 | 1242, 1983 | 2217, 4043 | 1199, 1994
Median (Min-Max) | 812 (420, 1740) | 810 (703, 1120) | 1603 (800, 2166) | 2950 (2060, 4840) | 1255 (420, 4840)
Actual Weight at Last Dosing Day
N | 10 | 5 | 9 | 7 | 31
Mean (SD) | 851 (365) | 902 (135) | 1646 (504) | 3273 (1289) | 1637 (1168)
95% CI of the Mean | 590, 1111 | 734, 1069 | 1258, 2033 | 2081, 4465 | 1208, 2065
Median (Min-Max) | 732 (373, 1680) | 895 (760, 1120) | 1650 (741, 2340) | 2950 (1990, 5720) | 1282 (373, 5720)
Actual Weight Change from Baseline to Last Dosing Day
N | 10 | 5 | 9 | 7 | 31
Mean (SD) | -21 (90) | 37 (61) | -80 (104) | 131 (347) | 6 (190)
95% CI of the Mean | -86, 43 | -39, 114 | -159, 0 | -190, 451 | -64, 75
Median (Min-Max) | -8 (-190, 120) | 57 (-61, 90) | -64 (-305, 60) | 0 (-100, 880) | -10 (-305, 880)

Note: Change is calculated by follow-up value minus baseline value.

Baseline visit can be the same as the first dosing day.

Table 14.3.4.1 Concomitant Medications Before the Start of Study Medication by ATC1 Drug Classification, Drug Name and GA/PNA Group Safety Population

ATC1 Drug Classification; Medication Name | Age Strata
ATC1 Drug Classification; Medication Name | GA 23-29 weeks; PNA <14 days; (N=10) | | GA 23-29 weeks; PNA 14-44 days; (N=5) | | GA 30-34 weeks; PNA <45 days; (N=9) | | GA 35-42 weeks; PNA <14 days; (N=8) | | All Participants; (N=32)
ATC1 Drug Classification; Medication Name | Participants With Medication N (%) | Total Medications N | Participants With Medication N (%) | Total Medications N | Participants With Medication N (%) | Total Medications N | Participants With Medication N (%) | Total Medications N | Participants With Medication N (%) | Total Medications N
ADRENERGIC AND DOPAMINERGIC AGENTS | 3 (30%) | 3 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 4 (12.5%) | 4
DOPAMINE | 3 (30%) | 3 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 4 (12.5%) | 4
ADRENERGIC AND DOPAMINERGIC AGENTS | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
EPINEPHRINE | 1 (10%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1

Note: The percentages are based on the total number of participants in each GA/PNA group or total.

Participants are counted once at each ATC1 Drug classification and drug name.

Table 14.3.4.2 Concomitant Medications After the Start of Study Medication by ATC1 Drug Classification, Drug Name and GA/PNA Group Safety Population

ATC1 Drug Classification; Medication Name | Age Strata
ATC1 Drug Classification; Medication Name | GA 23-29 weeks; PNA <14 days; (N=10) | | GA 23-29 weeks; PNA 14-44 days; (N=5) | | GA 30-34 weeks; PNA <45 days; (N=9) | | GA 35-42 weeks; PNA <14 days; (N=8) | | All Participants; (N=32)
ATC1 Drug Classification; Medication Name | Participants With Medication N (%) | Total Medications N | Participants With Medication N (%) | Total Medications N | Participants With Medication N (%) | Total Medications N | Participants With Medication N (%) | Total Medications N | Participants With Medication N (%) | Total Medications N
ADRENERGIC AND DOPAMINERGIC AGENTS | 5 (50%) | 5 | 1 (20%) | 1 | 0 | 0 | 2 (25%) | 2 | 8 (25%) | 8
DOPAMINE | 5 (50%) | 5 | 1 (20%) | 1 | 0 | 0 | 2 (25%) | 2 | 8 (25%) | 8
ADRENERGIC AND DOPAMINERGIC AGENTS | 1 (10%) | 1 | 1 (20%) | 1 | 0 | 0 | 2 (25%) | 2 | 4 (12.5%) | 4
EPINEPHRINE | 1 (10%) | 1 | 1 (20%) | 1 | 0 | 0 | 2 (25%) | 2 | 4 (12.5%) | 4
VASOPRESSIN AND ANALOGUES | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1
VASOPRESSIN | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 0 | 0 | 1 (3.1%) | 1

Note: The percentages are based on the total number of participants in each GA/PNA group or total.

Participants are counted once at each ATC1 Drug classification and drug name.

Table 14.3.5 Summary of Abnormal Physical Examination Findings by Body System and GA/PNA Group Safety Population

Body System | Age Strata | | | | Total; (N=32)
Body System | GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=9) | GA 35-42 weeks; PNA <14 days; (N=8) | Total; (N=32)
Number of Participants with Abnormal Findings ^1^ | 9 (90.0%) | 5 (100.0%) | 7 (77.8%) | 2 (25.0%) | 23 (71.9%)
General Appearance | 8 (80.0%) | 1 (20.0%) | 7 (77.8%) | 2 (25.0%) | 18 (56.3%)
General Behavior | 2 (20.0%) | 1 (20.0%) | 1 (11.1%) | 0 | 4 (12.5%)
Skin | 5 (50.0%) | 0 | 1 (11.1%) | 0 | 6 (18.8%)
Head | 2 (20.0%) | 0 | 0 | 0 | 2 (6.3%)
Eyes and Vision | 1 (10.0%) | 0 | 1 (11.1%) | 0 | 2 (6.3%)
Neck/Thyroid | 2 (20.0%) | 0 | 1 (11.1%) | 0 | 3 (9.4%)
Blood/Lymphatic | 8 (80.0%) | 1 (20.0%) | 7 (77.8%) | 2 (25.0%) | 18 (56.3%)
Cardiovascular | 5 (50.0%) | 1 (20.0%) | 2 (22.2%) | 1 (12.5%) | 9 (28.1%)
Respiratory | 9 (90.0%) | 4 (80.0%) | 4 (44.4%) | 0 | 17 (53.1%)
Abdomen | 1 (10.0%) | 5 (100.0%) | 0 | 2 (25.0%) | 8 (25.0%)
Nervous System | 1 (10.0%) | 3 (60.0%) | 1 (11.1%) | 1 (12.5%) | 6 (18.8%)
Musculoskeletal | 0 | 0 | 1 (11.1%) | 0 | 1 (3.1%)
Extremities | 0 | 2 (40.0%) | 1 (11.1%) | 0 | 3 (9.4%)
Other | 4 (40.0%) | 0 | 0 | 0 | 4 (12.5%)

Note: The percentages are based on the total number of participants in each PNA stratum or total.

1 Abnormal finding represents any non-clinically significant abnormal symptoms/disease that have been newly diagnosed or have worsened since last visit (or since informed consent for baseline visit).

Table 14.4.1 Summary of Study Doses by Protocol Dosing Group All Enrolled Participants

| Dosing group | | | | Total; (N=32)
| Version 1; 500mg/m^2^ q8; (N=13) | Version ≥2; 10 mg/kg q12; (N=9) | Version ≥2; 20 mg/kg q12; (N=4) | Version ≥2; 20 mg/kg q8; (N=6) | Total; (N=32)
Total Number of Study Doses Per Participant
Number of Participants | 13 | 9 | 4 | 6 | 32
Mean (SD) | 6.2 (2.5) | 5.3 (2.2) | 4.0 (1.8) | 7.7 (2.7) | 5.9 (2.5)
Median (Min, Max) | 6.0 (2.0, 11.0) | 6.0 (1.0, 9.0) | 4.0 (2.0, 6.0) | 9.0 (3.0, 10.0) | 6.0 (1.0, 11.0)
Study Doses (mg/kg)
Number of Doses | 80 | 48 | 16 | 46 | 190
Mean (SD) | 38.3 (7.5) | 15.3 (10.0) | 17.8 (3.7) | 28.5 (10.3) | 28.4 (13.0)
Median (Min, Max) | 37.7 (24.5, 52.6) | 10.6 (9.3, 38.5) | 18.7 (8.9, 21.2) | 21.2 (19.6, 46.8) | 29.9 (8.9, 52.6)
Number of Standard of Care Doses Before Study Dose Start
0 | 5 (38.5%) | 8 (88.9%) | 2 (50.0%) | 4 (66.7%) | 19 (59.4%)
1 | 5 (38.5%) | 0 | 0 | 0 | 5 (15.6%)
2 | 1 (7.7%) | 1 (11.1%) | 1 (25.0%) | 1 (16.7%) | 4 (12.5%)
3 | 1 (7.7%) | 0 | 1 (25.0%) | 1 (16.7%) | 3 (9.4%)
8 | 1 (7.7%) | 0 | 0 | 0 | 1 (3.1%)
Standard of Care Doses (mg/kg) (Before Study Dose Start)
Number of Doses | 18 | 2 | 5 | 5 | 30
Mean (SD) | 40.3 (9.9) | 36.5 (2.8) | 13.0 (5.1) | 35.9 (1.7) | 34.7 (12.7)
Median (Min, Max) | 39.1 (28.9, 52.6) | 36.5 (34.5, 38.5) | 9.6 (9.1, 18.6) | 36.9 (34.0, 37.3) | 34.3 (9.1, 52.6)
Number of Standard of Care Doses After Study Dose End
0 | 13 (100.0%) | 7 (77.8%) | 3 (75.0%) | 4 (66.7%) | 27 (84.4%)
1 | 0 | 1 (11.1%) | 1 (25.0%) | 2 (33.3%) | 4 (12.5%)
2 | 0 | 1 (11.1%) | 0 | 0 | 1 (3.1%)
Standard of Care Doses (mg/kg) (After Study Dose End)
Number of Doses | | 3 | 1 | 2 | 6
Mean (SD) | | 28.7 (16.0) | 17.8 | 34.4 (17.5) | 28.8 (14.2)
Median (Min, Max) | | 38.0 (10.2, 38.0) | 17.8 | 34.4 (22.0, 46.8) | 30.0 (10.2, 46.8)

Note: Dose in mg/kg uses participant’s actual weight.

Table 14.4.2 Summary of PK Sampling by GA/PNA Group PK Population

| Age Strata | | | | Total; (N=30)
| GA 23-29 weeks; PNA <14 days; (N=10) | GA 23-29 weeks; PNA 14-44 days; (N=5) | GA 30-34 weeks; PNA <45 days; (N=8) | GA 35-42 weeks; PNA <14 days; (N=7) | Total; (N=30)
Total Number of PK Samples Per Participant
N | 10 | 5 | 8 | 7 | 30
Mean (SD) | 5.7 (3.2) | 4.2 (0.8) | 4.5 (1.9) | 3.6 (1.0) | 4.6 (2.2)
Median (Min, Max) | 4.0 (3.0, 13.0) | 4.0 (3.0, 5.0) | 4.5 (2.0, 8.0) | 4.0 (2.0, 5.0) | 4.0 (2.0, 13.0)
Total Number of Plasma PK Samples Per Participant
N | 10 | 5 | 8 | 7 | 30
Mean (SD) | 5.2 (2.8) | 3.8 (0.8) | 3.9 (1.6) | 3.6 (1.0) | 4.2 (1.9)
Median (Min, Max) | 4.0 (3.0, 12.0) | 4.0 (3.0, 5.0) | 3.5 (2.0, 7.0) | 4.0 (2.0, 5.0) | 4.0 (2.0, 12.0)
Number of Timed Plasma PK Samples Per Participant
N | 10 | 5 | 8 | 7 | 30
Mean (SD) | 2.7 (1.1) | 3.0 (0.7) | 3.1 (0.8) | 3.6 (1.0) | 3.1 (0.9)
Median (Min, Max) | 3.0 (1.0, 4.0) | 3.0 (2.0, 4.0) | 3.0 (2.0, 5.0) | 4.0 (2.0, 5.0) | 3.0 (1.0, 5.0)
Number of Scavenged (Heparin or EDTA) Plasma PK Samples Per Participant
N | 7 | 3 | 3 | 0 | 13
Mean (SD) | 3.6 (2.7) | 1.3 (0.6) | 2.0 (1.7) | | 2.7 (2.3)
Median (Min, Max) | 3.0 (1.0, 9.0) | 1.0 (1.0, 2.0) | 1.0 (1.0, 4.0) | | 2.0 (1.0, 9.0)
Type of PK Samples
Total | 57 | 21 | 36 | 25 | 139
Plasma (fresh) | 27 | 15 | 25 | 25 | 92
Plasma (scavenged-EDTA) | 24 | 1 | 6 | 0 | 31
Plasma (scavenged-Heparin) | 1 | 3 | 0 | 0 | 4
Urine | 5 | 2 | 5 | 0 | 12

Table 14.4.3 Summary of PK Concentration Results by Protocol Dosing Group PK Population

| Dosing group | | | | Total; (N=30)
| Version 1; 500mg/m^2^ q8; (N=12) | Version ≥2; 10 mg/kg q12; (N=9) | Version ≥2; 20 mg/kg q12; (N=4) | Version ≥2; 20 mg/kg q8; (N=5) | Total; (N=30)
Total Number of Concentrations Measurements Per Participant
N | 12 | 9 | 4 | 5 | 30
Mean (SD) | 3.6 (1.0) | 5.9 (3.3) | 4.3 (1.0) | 5.2 (1.9) | 4.6 (2.2)
Median (Min, Max) | 4.0 (2.0, 5.0) | 4.0 (3.0, 13.0) | 4.5 (3.0, 5.0) | 5.0 (3.0, 8.0) | 4.0 (2.0, 13.0)
Number of Participants with PK Samples
Fresh Timed Plasma | 12 (100.0%) | 9 (100.0%) | 4 (100.0%) | 5 (100.0%) | 30 (100.0%)
Plasma (scavenged-EDTA) | 0 | 7 (77.8%) | 1 (25.0%) | 3 (60.0%) | 11 (36.7%)
Plasma (scavenged-Heparin) | 0 | 1 (11.1%) | 2 (50.0%) | 0 | 3 (10.0%)
Urine | 0 | 4 (44.4%) | 2 (50.0%) | 4 (80.0%) | 10 (33.3%)
Acyclovir Concentration (mg/L) of Fresh Timed Plasma Samples
N | 43 | 23 | 11 | 15 | 92
Mean (SD) | 45.8 (164.6) | 5.2 (5.3) | 6.8 (3.5) | 5.7 (2.2) | 24.5 (113.7)
Median (Min, Max) | 10.9 (0.7, 1080.0) | 3.8 (0.1, 19.0) | 6.1 (3.5, 15.8) | 5.1 (2.9, 10.0) | 5.9 (0.1, 1080.0)
Acyclovir Concentration (mg/L) of Scavanged Plasma Samples
N | 0 | 25 | 4 | 6 | 35
Mean (SD) | | 9.2 (7.5) | 8.1 (1.8) | 31.3 (66.5) | 12.9 (27.6)
Median (Min, Max) | | 5.5 (1.8, 25.5) | 8.6 (5.6, 9.7) | 4.9 (1.4, 167.0) | 5.6 (1.4, 167.0)
Acyclovir Concentration (mg/L) of Urine Samples
N | 0 | 5 | 2 | 5 | 12
Mean (SD) | | 272.4 (382.6) | 80.7 (40.1) | 1538.6 (1033.4) | 768.0 (953.5)
Median (Min, Max) | | 61.3 (23.1, 931.0) | 80.7 (52.3, 109.0) | 951.0 (599.0, 2990.0) | 442.5 (23.1, 2990.0)

Table 14.4.4 Summary of PK Concentration Results for Timed Fresh Plasma Samples by PK Sampling Windows and Protocol Group PK Population

Acyclovir Concentration (mg/L) | Version 1; (N=12) | Acyclovir Concentration (mg/L) | Version ≥2; (N=18)
First Dose: 0-5 minutes after | | First Dose: 0-15 minutes after
N of Samples | 2 | N of Samples | 3
Mean (SD) | 6.1 (2.3) | Mean (SD) | 5.1 (2.7)
Median (Min, Max) | 6.1 (4.4, 7.7) | Median (Min, Max) | 5.2 (2.4, 7.7)
First Dose: 2-4 hours after | | First Dose: 30 minutes prior to second dose
N of Samples | 5 | N of Samples | 8
Mean (SD) | 5.5 (2.4) | Mean (SD) | 2.4 (1.4)
Median (Min, Max) | 5.9 (2.8, 8.7) | Median (Min, Max) | 2.1 (0.7, 5.1)
First Dose: 6-8 hours after
N of Samples | 1
Mean (SD) | 3.2
Median (Min, Max) | 3.2
Dose 5 - Dose 15: immediately prior | | Dose 5-6 (Group 1-2) OR Dose 8-9 (Group 3): 30 minutes prior
N of Samples | 8 | N of Samples | 6
Mean (SD) | 5.9 (4.0) | Mean (SD) | 5.4 (2.7)
Median (Min, Max) | 4.8 (0.7, 12.8) | Median (Min, Max) | 5.5 (1.7, 8.5)
Dose 5 - Dose 15: 0-5 minutes after | | Dose 5-6 (Group 1-2) OR Dose 8-9 (Group 3): 0-15 minutes after
N of Samples | 3 | N of Samples | 2
Mean (SD) | 367.9 (616.7) | Mean (SD) | 10.3 (7.8)
Median (Min, Max) | 12.8 (10.9, 1080.0) | Median (Min, Max) | 10.3 (4.8, 15.8)
Dose 5 - Dose 15: 2-4 hours after | | Dose 5-6 (Group 1-2) OR Dose 8-9 (Group 3): 2-3 hours after
N of Samples | 5 | N of Samples | 2
Mean (SD) | 52.0 (57.7) | Mean (SD) | 4.8 (0.1)
Median (Min, Max) | 15.4 (5.8, 120.0) | Median (Min, Max) | 4.8 (4.7, 4.8)
Dose 5 - Dose 15: 6-8 hours after | | Last Dose: 15-18 hours after
N of Samples | 8 | N of Samples | 0
Mean (SD) | 15.8 (11.4) | Mean (SD)
Median (Min, Max) | 13.4 (3.5, 35.1) | Median (Min, Max)

Figure 14.3.1.1 Summary of Clinical Laboratory Hematology Measurements: White Blood Count (10^3^/mm^3^) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.1.2 Summary of Clinical Laboratory Hematology Measurements: Hematocrit (%) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.1.3 Summary of Clinical Laboratory Hematology Measurements: Platelet Count (10^3^/mm^3^) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.1.4 Summary of Clinical Laboratory Hematology Measurements: Neutrophils (%) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.1.5 Summary of Clinical Laboratory Hematology Measurements: Lymphocytes (%) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.1.6 Summary of Clinical Laboratory Hematology Measurements: Bands (%) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.1 Summary of Clinical Laboratory Serum Chemistry Measurements: Creatinine (mg/dL) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.2 Summary of Clinical Laboratory Serum Chemistry Measurements: BUN (mg/dL) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.3 Summary of Clinical Laboratory Serum Chemistry Measurements: AST (U/L) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Values above 1000 are excluded from the figure, but are included in the calculations (▬ AST value of 4383 U/L at baseline).

Figure 14.3.2.4 Summary of Clinical Laboratory Serum Chemistry Measurements: ALT (U/L) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.5 Summary of Clinical Laboratory Serum Chemistry Measurements: A lkaline Phosphatase (U/L) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.6 Summary of Clinical Laboratory Serum Chemistry Measurements: Total Bilirubin (mg/dL) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.7 Summary of Clinical Laboratory Serum Chemistry Measurements: Direct Bilirubin (mg/dL) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.8 Summary of Clinical Laboratory Serum Chemistry Measurements: Sodium (mmol/L) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.9 Summary of Clinical Laboratory Serum Chemistry Measurements: Potassium (mmol/L) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.10 Summary of Clinical Laboratory Serum Chemistry Measurements: Calcium (mg/dL) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.2.11 Summary of Clinical Laboratory Serum Chemistry Measurements: Albumin (g/dL) by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Figure 14.3.3 Summary of Actual Weight by Visit Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value.

The change value is the last dosing day value minus the baseline value.

Note: One participant had a last dosing day weight of 5720g and a change of 880g from baseline to last dosing day. These values are included in the calculations but not shown on the figure.

SAE Narratives Have Been Redacted to Protect Participant Privacy