# 5 Ethics

## 5.1 Institutional Review Board (IRB)

Institutional Review Board (IRB) approval of the protocol, informed consent, and participant information and/or advertising as relevant was obtained prior to the authorization of study commencement at the site. Any amendments to the protocol received IRB approval prior to implementation of any changes made to the study design. Detailed IRB information is provided in Appendix 16.1.3.

## 5.2 Ethical Conduct of the Study

This study was conducted in accordance with the ethical principles originating from the Declaration of Helsinki and current GCP and in compliance with local and federal regulatory requirements.

## 5.3 Participant Information, Consent, and Assent

All participants in this study were infants. The investigator or designated representative explained the nature of the study to the participant’s parents or legal guardian, to the extent compatible with his/her understanding, and answered all questions regarding this study. Prior to any study related screening procedures being performed on the participant, the informed consent (parental permission) statement was signed and dated by the participant’s parent or legal guardian and by the person who administered the informed consent. Since the participants were infants, no assents were obtained. A copy of the informed consent form (ICF) was given to the participant’s parents or legal guardian, and the original was placed in the participant’s medical record. An entry was also made in the participant’s source documents to confirm that informed consent was obtained prior to any study-related procedures and that the participant, or the participant’s parents or legal guardian, received a signed copy. In addition, the Health Insurance Portability and Accountability Act (HIPAA) statement was reviewed, signed, and dated by the participant’s parent or legal guardian. A sample ICF is provided in Appendix 16.1.3.