# 16 Appendices

16.1 Study Information
  16.1.1 Protocol and Protocol Amendments
  16.1.2 Sample Case Report Form
  16.1.3 Institutional Review Boards (IRB) and Consent Information
  16.1.4 Description of Investigators
  16.1.5 Signature Page
  16.1.6 Listing of Study Drug Batch Numbers
  16.1.7 Randomization Scheme and Codes
  16.1.8 Audit Certificates
  16.1.9 Statistical Analysis Plan
  16.1.10 Documentation of Inter-laboratory Standardization Methods and Quality Assurance Procedures
  16.1.11 Publications Based on the Study
  16.1.12 Important Publications Referenced in the Report
16.2 Participant Data Listings
16.3 Case Report Forms for Participants with SAEs
16.4 Miscellaneous
  16.4.1 PK Report
  16.4.2 PK Base Model NONMEM Datasets, Control Streams, and Output
  16.4.3 PK Final NONMEM Datasets, Control Streams, and Output
  16.4.4 PK Simulation Datasets, Control Streams, and Output
  16.4.5 PK Data Dictionary (PK_Define.pdf and Notes Regarding Conversion to XPT)
  16.4.6 PK Supplemental Report
  16.4.7 Assay Validation Report
  16.4.8 Bioanalytical Study Report
16.5 Datasets and Define.pdf
  16.5.1 NICHD-2011-ACY01 Datasets
  16.5.2 NICHD-2011-ACY01 Data Dictionary (ACY01-define.pdf)

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/15961