# Archive Issues, 1994-2008

Online and PDF versions of previous are available by clicking on the links below:

## January 2008

dbGaP; Web BLAST Interface Redesign; Genome Builds and Map Viewer; New Protein Cluster Database; GenBank Release 164; RefSeq Release 27; BLAST Lab (PDF)

## Fall/Winter 2006/07

PubMed Abstract Plus; CDTree & Cn3D; Whole Genome Shotgun; New BLAST View; New Genome Builds; UniGene; RefSeq Release 22; GenBank Release 158; NCBI Courses; Submissions Corner; PubChem Grows to 15MM (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/V15N2/index.html), PDF)

## Summer 2006

Influenza Database and Tools; Trace Archives at 1 Billion; Entrez Nucleotide Split Database; Third Party Annotation Database; RefSeq Release 18; 1918 Killer Flu Virus; UniGene; GenBank Release 155; Mammoths and Moas at NCBI; Recent NCBI Pubs; NCBI Papers Most Cited; NCBI Courses; BLAST Lab; Genome Builds and Map Viewer. (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/V15N1/index.html), PDF)

## November 2005

OMSSA; Probe Database Debut; New Structure Link from Protein; BLAST Download Update; New Microbial Genomes; Nucleotide Database Splits; NCBI 4-Pack Course; RefSeq Release 14; New Organisms in UniGene; GenBank Passes 100 Gigabases; New BLAST Formatter; Splign Alignment Tool; GenBank Release 150; New Genome Builds; Submission Corner (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/V14N2/index.html), PDF)

## May 2005

GENSAT; My NCBI; Influenza Virus Resource; NCBI Toolkit; New Microbial Genomes; Iceman Preserved; RefSeq Updates; RefSeq Release; UniGene; GenBank Release 147; New Genome Build; CCDS Database; NCBI Courses; PubMed Corrects Spelling; BLAST Lab; LocusLink Retired (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/V14N1/index.html), PDF)

## Summer/Fall 2004

Entrez E-Utilities; PubChem; GenePlot; New NLM Catalog; New Genome Builds; New Microbial Genomes in GenBank; Whole Genome Shotgun Project Page; New Format Option Web BLAST; Trace Archive Grows; New Organisms in UniGene; RefSeq Version 8; Submissions Corner; Predicted Records; GenBank Release 144; BLAST 2.2.10 Released; Recent Publications (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/SummerFall04/index.html), PDF)

## Spring 2004

Transitioning from LocusLink to Entrez Gene; New Cancer Chromosomes Database; HomoloGene's New Look; BLAST Link (BLink); Debut of the HCT Database; 350KB Sequence Length Limit Removed; New Eukaryotic Genomes; Environmental Samples; HIV Protein-Interaction Database; e-PCR and Reverse e-PCR; New Organisms in UniGene; RefSeq Accession Numbers Get Longer; FieldGuidePlus Course; RefSeq Release 6; GenBank Release 142; Entrez Tools 'Hot Spot'; BLAST Lab; New Microbial Genomes; Entrez Quiz (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Spring04/index.html), PDF)

## Fall/Winter 2003

Entrez Query Goes "Global"; Register Your Genome Project; New Genome Builds; Entrez Gene Database; Recent Publications; New Microbial Genomes; KOGs and COGs in CDD; Submission Corner; GenBank Release 139; UniGene Adds Four; RefSeq Version 3 (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/FallWinter03/index.html), PDF)

## Summer 2003

Reference Human Genome; SARS Coronavirus Resource; Gene Expression Omnibus (GEO); Major Histocompatibility Complex (dbMHC); RefSeq Release 1; GenBank Release 137; New Microbial Genomes; Sequence Revision History; BLAST Lab (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Summer03/index.html), PDF)

## Spring 2003

Field Guide to GenBank; Human Reference Sequence; UniGene Expands; Rat Genome Assembly; Taxonomy Browser; Search the NCBI Web Site; Recent Publications; New Genomes; Entrez Quiz; Submission Corner; GenBank Updates; GenBank Release 135 (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Spring03/index.html), PDF)

## Fall/Winter 2002

Plasmodium falciparum Genome; Third Party Annotation Database; Map Viewers; Structure Similarities; PubMed Central; The NCBI Handbook; BLAST Lab; New Microbial Genomes (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/FallWinter02/index.html), PDF)

## Summer 2002

Cn3D 4.0; SNP Population Grows; Viral Reference Sequences; New Genomes in GenBank; Mouse Genome Resources; Mosquito Genome; Sequin MacroSend; BLAST version 2.2.4 (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Summer02/index.html), PDF)

## Spring 2002

Model Maker; Virus Reference Sequences; New MapViewer Displays; Mouse Genome BLAST; Organism-Specific BLAST; ProtEST; Trace Archive Expands; Find Out "About NCBI"; New FTP Hierarchy; Barbara Rapp Leaves NCBI (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Spring02/index.html), PDF)

## Winter 2001

COGs Update; Plant Genomes; LinkOut; Investigator Profile: Stephen Altschul; GenBank News; Expanded Bookshelf; BLAST Enhancements (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Winter01/index.html), PDF)

## Fall 2001

Using TaxPlot to Compare Genomes; New RefSeq Accession Numbers for Curated Genomic Regions; GenBank News; DART Targets Protein Domains; Evidence Viewer Facilitates Analysis of NCBI Human Gene Models (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Fall01/index.html), PDF)

## Spring 2001

Human Genome Map Viewer; Investigator Profile: Eugene V. Koonin; Mouse Genome Resources; UniSTS Integrates Markers; GenBank Mirror Sites; New BLAST Features (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Spring01/map_viewer.html), PDF)

## Fall / Winter 2000

The Human Genome Sequence; BLink Enhances Entrez Exploration; Human Gene Nomenclature; Standalone BLAST Additions; Mirror FTP Site for GenBank (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/FallWinter2000/human_genome.html), PDF)

## Summer 2000

Conserved Domain Database; Enhanced Taxonomy Access; New Human-Mouse Homology Map; Gene Expression Omnibus; GenBank Adds a Pair of Pathogens; Protein Molecular Weight in Entrez; OMIM in Entrez; Web Server Software for BLAST; PSI-BLAST 2.1; Address Change for FTP Server (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Summer00/conserved.html), PDF)

## Spring 2000

Dazzling Graphics with Cn3D 3.0; BLAST Offers Taxonomic Views; HomoloGene: Clusters of Clusters; Fly Genome Deposited in GenBank; Drosophila Finds New Home Page; Human Genome Map Viewer (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Spring00/cn3d.html), PDF)

## Winter 2000

Entrez Genomes; IgBLAST; BLAST 1.4; PubMed Central; Mitochondria Energize RefSeq; PSI-BLAST Profiles; Textbooks Linked to PubMed; BankIt 3.0; Mouse and Rat in LocusLink; Malaria Menace Mapped (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Winter00/entrez_genomes.html), PDF)

## Fall 1999

Enhanced Entrez; New Home Page; Cn3D 2.5; News Briefs; GenBank Contig Division; VecScreen; BLAST Lab (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Fall99/entrez.html), PDF)

## Summer 1999

Decade of Data; LocusLink; QBlast; Cn3D 2.5 Released; RefSeq; Exhibits and Workshops; Coffee Break (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Summer99/decade.html), PDF)

## Spring 1999

Human Genome Resource; Sequences from Times Past; Sequin 2.90; SAGEmap; Profile: PSI-BLAST Team; BLAST Lab; Protocol for EST Submissions (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Spring99/spring99.htm), PDF)

## Winter 1999

Submitting Alignments; Compound Accession Number; HIV-1 Subtyping Tool; Changes to BLAST Output; UniGene for Rat; BLAST Lab: Standalone BLAST; Profile: CASP3 Winners (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Winter99/winter99.htm), PDF)

## November 1998

GeneMap '98; Cn3d 2.0; PHI-BLAST; Submitting Identical Sequences from Multiple Sources; Authorin No Longer Accepted; Genes and Disease Web Site; Flexibility Added to BLAST; dbSNP; NCBI Marks 10th Anniversary (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/Nov98/nov98.htm), PDF)

## July 1998

Complete Genomes in GenBank; Unfinished Microbial Genomes; Tracking Human Sequencing; BLAST 2 Sequences; GeneMap '98; New Network Clients; Malaria Genetics Web Site (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/july98.html), PDF)

## February 1998

BLAST Version 2.0; COGs; GenBank Submissions; High Throughput Sequencing; GenBank Reaches One Billion (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/feb98.html), PDF)

## August 1997

PubMed Launched; Using Sequin; Structure Neighbors; ORF Finder; Electronic PCR; CGAP Revolutionizes Research (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/aug97.html), PDF)

## August 1996

See in 3D: New Entrez Release; UniGene Collection; Entrez CD-ROM Discontinued; QUERY E-mail Server; Human/Mouse Homology Map; Images in OMIM; Genome Survey Sequences; Sequin Quick Guide; New BLAST Services (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/aug96.html), PDF)

## March 1996

OMIM Database Available; Entrez: Graphical Views of the Genomes Division; Sequin Pre-Release; Entrez in Secure Environments; BLAST Service Update; Entrez CD-ROM Discontinued (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/mar96.html), PDF)

## September 1995

GenBank Enters Megabase Era; Entrez Takes Graphical View; GenBank Taxonomy; BankIt Submissions Mount (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/sept95.html), PDF)

## March 1995

GenBank Offers BankIt; GenBank Receives Merck Sequences; Entrez on the Net; Molecular Modeling Database; GenBank Fellows (HTML (http://www.ncbi.nlm.nih.gov/Web/Newsltr/mar95.html), PDF)

## August 1994

Mosaic Adds dbEST/dbSTS; Entrez CD-ROM's Third Year; Repository CD-ROM Service Ends; GenBank Fellows; Entrez Replaces NCBI-Sequences; GenBank Flat File Expands; Profile: Dan Graur; Special: GenBank Services (PDF)

## February 1994

GenBank's Taxonomy; Access NCBI Through WWW; New STS Database, Division; CD-ROM Entrez Expands; GenBank: Focus on Quality; NCBI's Board; NCBI Services (PDF)