# NCBI News, December 2008

## Featured Resource: BLAST 2 Sequences Is Now Part of the Main BLAST Web Service

The former BLAST utility program Blast 2 Sequences is now available on all main BLAST Web forms. This program eliminates the need for the separate service formerly linked as a specialized BLAST page. More importantly, the service now provides the full functionality of the Web BLAST engine, the BLAST formatter, and the ability compare more than one sequence in a single search.

### Accessing and Using the Service

A Blast 2 Sequences checkbox is now available on all BLAST forms linked to the Basic BLAST section of the BLAST homepage (blast.ncbi.nlm.nih.gov). The old Blast 2 Sequences link on the BLAST Homepage will link directly to the Basic Nucleotide form already set up for Blast 2 Sequences. On the BLAST submission page, checking the Blast 2 Sequences checkbox changes the form so that the database selection portion is eliminated, and a new text area appears for entering target sequences (Figure 1). The newly added program tabs allow rapid selection of a different program if desired (blastp, blastn, blastx, tblastn, tblastx). Sequences in FASTA format or database accession numbers may be entered in either of the two text areas. Sets of sequences may also be uploaded to the service from files on disk. The ability to enter multiple sequences makes it possible to search a small custom database on the web or to perform an all-against-all comparison of a small number of sequences.

### Output Format

The Blast 2 Sequences output provides a completely redesigned dot plot of the alignment that features a higher resolution display than the old Blast 2 Sequences service. The dot-plot may be collapsed if desired. The dot-plot is useful in many cases for identifying repeated domains in proteins or insertions, inversions, and translocations in nucleotide sequences. Figure 2 shows the dot-plot of the alignment of two bacterial genomes with large-scale relative rearrangements. The rearrangements are easily visible in the plot.

All formatting options available for the main Web BLAST service are also available for Blast 2 Sequences. These options include alternative alignment views such as pairwise, query anchored with mismatch and identity highlighting, and downloadable structured formats such as ASN.1, XML, and hit table. The ability to display results as a distance tree using the BLAST Treeview link is particularly useful when the Blast 2 Sequences option is used with a small custom database as shown in Figure 3 for selected vertebrate aromatic amino acid hydroxylases.

### Summary

The Blast 2 Sequences utility is now fully integrated into the main NCBI BLAST service, providing the full power of the Web BLAST service along with flexible formatting options for comparing two sequences. This feature also extends the capability of Blast 2 Sequences to make it a “Blast several Sequences” service. These expanded options and abilities make Blast 2 Sequences a new, powerful, and flexible sequence analysis tool.

## New Databases and Tools

### PMID : PMCID Converter

A converter is available to translate ID numbers for articles found in both PubMed and PubMed Central. The converter will convert IDs from PubMed to PMC and vice versa. It can be found at: http://www.ncbi.nlm.nih.gov/sites/pmctopmid

### Bookshelf

The Bookshelf has added two new books entitled: The Epilepsies: Seizures, Syndromes, and Management and Essentials of Glycobiology. Books can be found at: www.ncbi.nlm.nih.gov/sites/entrez?db=Books.

### Genome Resource Guide

An Aphid Genome Resource page is available at: www.ncbi.nlm.nih.gov/projects/genome/guide/aphid/ . This page provides a gateway to aphid resources both within NCBI and the outside scientific community.

### Microbial Genomes

Fifteen finished microbial genomes were released from October 10-November 17. The original sequence data files submitted to GenBank/EMBL/DDBJ can be found at: ftp.ncbi.nih.gov/genbank/genomes/Bacteria/. The RefSeq provisional versions of these genomes are available via FTP at: ftp.ncbi.nih.gov/genomes/Bacteria/.

## GenBank News

GenBank release 168.0 is available via web and FTP that includes information as of October 27, 2008. The database increased by 19.84 Gigabases since the last release, 167.0. This is a milestone for the largest growth between single releases.

## Updates and Enhancements

### RefSeq

RefSeq Release 32 is available via web and FTP. This full release incorporates genomic, transcript, and protein data available as of November 7, 2008 and includes 9,145,702 records from 5,513 different organisms. The RefSeq website is: www.ncbi.nlm.nih.gov/RefSeq/.

RefSeq records for microbial projects with the prefix ‘NZ’ will now include two style formats where there may be 2 or 4 alphabetic characters following the underscore. These new accession formats have been designed to support duplicating WGS microbial scaffolds and complete genomic models when a project is a mixture of contigs and scaffolds.

### Genome Assembly

Genome annotation for Anopheles gambiae build AgamP3.3 and Caenorhabitis elegans build WS190 were released in October. For more annotation updates and links to Genome Resource pages see: www.ncbi.nlm.nih.gov/Genomes/.

## Announce Lists and RSS Feeds

Fifteen topic-specific mailing lists are described on the Announcement List summary page. Announce lists provide email announcements about changes and updates to NCBI resources. www.ncbi.nlm.nih.gov/Sitemap/Summary/email_lists.html

Seven RSS feeds are now available from NCBI including news on PubMed, PubMed Central, NCBI Bookshelf, LinkOut, HomoloGene, UniGene, and NCBI Announce. Please see: www.ncbi.nlm.nih.gov/feed/

Comments and questions about NCBI resources may be sent to NCBI at: info@ncbi.nlm.nih.gov, or by calling 301-496-2475 between the hours of 8:30 a.m. and 5:30 p.m. EST, Monday through Friday.

Figure 1 The new Blast 2 Sequences option on the Basic nucleotide BLAST form

Either one or many sequences can be entered into the two text areas or uploaded from files. Rapid access to other BLAST programs is available through the tabs at the top of the form.

Figure 2 The expanded Dot Matrix view from Blast 2 Sequences showing the alignment of two Salmonella enterica subsp. enterica genome sequences (serovar Heidelberg str. SL476, accession NC_001083 and serovar Typhi Ty2, accession NC_004631)

Three large-scale relative inversions and a smaller translocation are apparent as cross diagonal matches. Shared repetitive sequences appear as a characteristic set of off- diagonal column and row matches.

Figure 3 A portion of the BLAST Treeview generated from the Blast 2 Sequences results for the alignment of human phenylalanine hydroxylase (accession NP_00068) with a set of 34 other vertebrate aromatic amino acid hydroxylases

The portion shown here contains the tryptophan hydroxlase 1 homologs from human (Homo sapiens), NP_004170; rabbit (Oryctolagus cuniculus), NP_001093425 and NP_001075741; mouse (Mus musculus), NP_033440; rat (Rattus norvegicus), NP_001094104; chicken (Gallus gallus), NP_990287; Xenopus laevis, NP_001080923; zebrafish (Danio rerio), NP_001001843 and NP_840091; and pufferfish (Takifugu rubripes), NP_001027848.