# NCBI News, April 2015

## May 6th webinar: "The NCBI Minute: Connecting with PubMed Commons"

Monday, April 27, 2015

Next Wednesday, May 6th, NCBI staff will introduce PubMed Commons (https://www.ncbi.nlm.nih.gov/pubmedcommons), a forum for sharing information and perspectives about biomedical publications in PubMed. We will also provide a brief overview of how to participate and highlight the ways users are contributing to scientific discourse.

To sign up for this short webinar, click here (https://attendee.gotowebinar.com/register/5466135561815368962). Like all of our webinars, this will be posted on the NCBI YouTube account (https://www.youtube.com/user/NCBINLM) after the live presentation.

The NCBI Minute is a series of short webinars that give a brief introduction to a specific topic or NCBI tool. To see upcoming webinars, as well as summaries, YouTube recordings (https://www.youtube.com/playlist?list=PLH-TjWpFfWrt-lX_ltntX1M75KBXb03g9) and related materials from past webinars, please see the NCBI Webinars page (https://www.ncbi.nlm.nih.gov/home/coursesandwebinars.shtml).

## New NCBI Insights blog post: "NIHMS Users: Do You Know How Often Your Paper is Being Accessed via PMC?"

Thursday, April 23, 2015

The latest blog post on NCBI Insights (http://ncbiinsights.ncbi.nlm.nih.gov/2015/04/24/nihms-users-do-you-know-how-often-your-paper-is-being-accessed-via-pmc-heres-how-to-find-out/) shows NIHMS users how to view PMC access statistics for any paper with which they are associated in the NIHMS system.

NIHMS manuscript list

Visit NCBI Insights (http://ncbiinsights.ncbi.nlm.nih.gov/), the official NCBI blog, for stories about what's new at NCBI, quick tips for using our tools, and science features.

## April 29th webinar: "The NCBI Minute: Finding Genomes and Annotations by Searching NCBI Assembly"

Wednesday, April 22, 2015

Next Wednesday, April 29th, NCBI staff will show you how to quickly find a particular genome sequence by using FTP to access our Assembly (https://www.ncbi.nlm.nih.gov/assembly) database, which houses 25,000 annotated genomes.

To sign up for this short webinar, click here (https://attendee.gotowebinar.com/register/2241676975542351106). Like all of our webinars, this will be posted on the NCBI YouTube account (https://www.youtube.com/user/NCBINLM) after the live presentation.

The NCBI Minute is a series of short webinars that give a brief introduction to a specific topic or NCBI tool. To see upcoming webinars, as well as summaries, YouTube recordings (https://www.youtube.com/playlist?list=PLH-TjWpFfWrt-lX_ltntX1M75KBXb03g9) and related materials from past webinars, please see the NCBI Webinars page (https://www.ncbi.nlm.nih.gov/home/coursesandwebinars.shtml).

## April 21st webinar: Rebroadcast of "NCBI and the NIH Public Access Policy: PubMed Central Submissions, My NCBI, My Bibliography and SciENcv"

Tuesday, April 14, 2015

On Tuesday, April 21, NCBI will have an encore presentation of the March 5th webinar for NIH grant holders on My NCBI, My Bibliography and SciENcv. This webinar will include the same material as the March 5th webinar; the recording of the original presentation is available on YouTube (https://www.youtube.com/watch?v=2ze2PNHvLYk).

To register for the April 21st webinar, go here (https://attendee.gotowebinar.com/register/1865031570666755074).

To see upcoming webinars, as well as summaries, YouTube recordings (https://www.youtube.com/playlist?list=PLH-TjWpFfWrt-lX_ltntX1M75KBXb03g9) and related materials from past webinars, please see the NCBI Webinars page (https://www.ncbi.nlm.nih.gov/home/coursesandwebinars.shtml).

## April 15th webinar: "The NCBI Minute: Finding and Getting the Data You Want from NCBI in Less than Three Minutes - Introducing BioProject'

Friday, April 10, 2015

Next Wednesday, April 15th, NCBI staff will show you how to use the BioProject database (https://www.ncbi.nlm.nih.gov/bioproject) to quickly find data. When looking for research data using fairly broad search terms like "tuberculosis" or "mouse", BioProject is a great place to start. In this brief presentation, you will learn how to search for studies and quickly identify related PubMed-listed publications and experimental data, such as RNA-seq datasets in the GEO database.

To sign up for this webinar, go here (https://attendee.gotowebinar.com/register/5904867089245135617).

The NCBI Minute is a series of short webinars that give a brief introduction to a specific topic or NCBI tool. To see upcoming webinars, as well as summaries, recordings (via YouTube (https://www.youtube.com/playlist?list=PLH-TjWpFfWrt-lX_ltntX1M75KBXb03g9)) and related materials from past webinars, please see the NCBI Webinars page (https://www.ncbi.nlm.nih.gov/home/coursesandwebinars.shtml).

## NIH issued statement on use of dbGaP in the Cloud

Thursday, April 02, 2015

On Monday, the National Institutes of Health announced that it is now allowing investigators to request permission to transfer controlled-access genomic and associated phenotypic data obtained from NIH-designated data repositories, like dbGaP, under the auspices of the NIH Genomic Data Sharing (GDS) policy (http://gds.nih.gov/03policy2.html) to public or private cloud systems for data storage and analysis.

Please keep in mind that the responsibility for the security of the dbGaP data is assumed by each investigator and their associated institution who has been approved to access the data, not the cloud provider. To assist in this process, NIH has provided as much information as possible for PIs, institutional signing officials and the IT staff who will be supporting these projects.

The post "The Cloud, dbGaP and the NIH" (https://nihdatascience.wordpress.com/2015/03/26/the-cloud-dbgap-and-the-nih/) on the NIH Data Science blog (https://nihdatascience.wordpress.com) discusses the NIH position statement, the Genomic Data Sharing policy, and best practices (https://www.ncbi.nlm.nih.gov/projects/gap/cgi-bin/GetPdf.cgi?document_name=dbgap_2b_security_procedures.pdf), as well as NIH's IT security requirements and policies.