# NCBI News, December 2009

## New Databases and Tools

### PubMed Central

The PubMed Central URL has been redesigned to allow for easier usability as well as consistency across the NCBI site. The previous site, www.pubmedcentral.gov, has been moved into the NCBI domain as a sub-site. The PMC home page can be accessed at www.ncbi.nlm.nih.gov/pmc/.

PMC also now provides a “Preview” Table of Contents for embargoed journal issues for which at least one article has been released in PMC. The embargoed articles will be released according to the date reflected in the table of contents.

### Microbial Genomes

Six finished microbial genomes were added to the NCBI databases between November 25 and December 31, 2009. The original sequence data files submitted to GenBank/EMBL/DDBJ are on the FTP site: [underlined: ftp.ncbi.nih.gov/genbank/genomes/Bacteria/]. The RefSeq provisional versions of these genomes are also available: ftp.ncbi.nih.gov/genomes/Bacteria.

## GenBank News

GenBank release 175.0 is available on the NCBI Web Service and FTP site. The current release incorporates sequence data as of December 15, 2009. Release notes (gbrel.txt (ftp://ftp.ncbi.nih.gov/genbank/gbrel.txt)) describing details of the release and upcoming changes are in the GenBank FTP directory.

## Updates and Enhancements

### Entrez Utilities Policy Change

Effective June 1, 2010, all E-Utility requests must contain non-null values for both &tool and &email parameters. Standard usage policies are described on the following page: http://eutils.ncbi.nlm.nih.gov/entrez/query/static/eutils_help.html#UserSystemRequirements. If you have any concerns or questions about the policies, please contact eutilities@ncbi.nlm.nih.gov.

### My Bibliography

The My NCBI My Bibliography tool has been enhanced to allow users to add citations from books, meetings, presentations, patents, and articles not found in PubMed. The About My NCBI page provides information on how to use the tool to the best of its ability: www.ncbi.nlm.nih.gov/sites/myncbi/about/.

### Exhibits

NCBI will exhibit at the American Association for the Advancement of Science Conference on February 18-22 in San Diego, California.

## Announce Lists and RSS Feeds

NCBI offers eighteen topic-specific mailing lists that provide email announcements about changes and updates to NCBI resources including dbGaP, BLAST, GenBank, Structures, Conserved Domains, BioSystems and Sequin. The various lists are described on the Announcement List summary page: www.ncbi.nlm.nih.gov/Sitemap/Summary/email_lists.html. To receive updates on the NCBI News, please see: www.ncbi.nlm.nih.gov/About/news/announce_submit.html

Seven RSS feeds are now available from NCBI including news on PubMed, PubMed Central, NCBI Bookshelf, LinkOut, HomoloGene, UniGene, and NCBI Announce. Please see: www.ncbi.nlm.nih.gov/feed/

Comments and questions about NCBI resources may be sent to NCBI at: info@ncbi.nlm.nih.gov, or by calling 301-496-2475 between the hours of 8:30 a.m. and 5:30 p.m. EST, Monday through Friday.