# Glossary

Term: Definition
Cancer survivors: A population with a history of a cancer diagnosis, referring to individuals who have completed treatment for active cancer, who have metastatic disease, or who require intermittent treatment.
EHR problem list: A list used within electronic health records (EHR) that outlines the illnesses, injuries, and other factors affecting the health of a patient, usually identifying symptoms, time of occurrence, diagnosis, and treatment or resolution.
Electronic nicotine delivery systems: Electronic nicotine delivery systems (ENDS) represent a rapidly changing class of tobacco products known by many different names, including e-cigarettes, e-cigs, vapes, mods, and tank systems. ENDS deliver an aerosol to the user that typically contains nicotine, propylene glycol, vegetable glycerin, and flavoring chemicals.
Long-term abstinence: Typically refers to 6 or more months without tobacco product use.
Medically underserved and vulnerable populations: Populations who experience disparities in cancer burden, smoking prevalence, access to smoking cessation treatment, and/or smoking cessation treatment success. For the purposes of this monograph, ‘vulnerable’ refers to a heightened risk for cancer or a higher cancer burden relative to the general population. Medically underserved and vulnerable populations discussed in this monograph include socioeconomically disadvantaged populations, racial and ethnic minority populations, rural populations, sexual and gender minority (SGM) populations, individuals with co-occurring substance use disorders, and individuals with serious mental illness (SMI).
Pack year: A way to measure the amount a person has smoked over a period of time. It is calculated by multiplying the number of packs of cigarettes smoked per day by the number of years the person has smoked. For example, 1 pack year is equal to smoking 1 pack per day for 1 year, or 2 packs per day for half a year.
Patients with cancer: Refers to those newly diagnosed with cancer and in treatment for active or recurrent cancer.
Smoking: Refers to cigarette use.
Smoking cessation treatment: Encompasses treatment aimed at smoking reduction, smoking cessation, and relapse prevention after treatment.
Tobacco use: Refers to use of tobacco products including cigarettes, cigars, hookah, ENDS, and smokeless tobacco.