# Acknowledgments

## Scientific Editorial Committee (SEC)

### Chairs

- Timothy Baker, Ph.D.
  Director of Research
  University of Wisconsin Center for Tobacco Research and Intervention
  University of Wisconsin-Madison
  Madison, Wisconsin
- Michael Fiore, M.D., M.P.H., M.B.A.
  Director
  University of Wisconsin Center for Tobacco Research and Intervention
  University of Wisconsin-Madison
  Madison, Wisconsin
- Gordon Willis, Ph.D.
  Program Director
  Tobacco Control Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland

### Members

- Monica Webb Hooper, Ph.D.
  Deputy Director
  National Institute on Minority Health and Health Disparities
  National Institutes of Health
  Bethesda, Maryland
- Anne Joseph, M.D., M.P.H.
  Wexler Professor of Medicine
  Division of General Internal Medicine
  Department of Medicine
  University of Minnesota Medical School
  Minneapolis, Minnesota

### Managing Editor

- Kristen Mangold, M.S.W.
  Public Health Advisor
  Tobacco Control Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland

## Chapter Leads

- Lisa A. Peterson, Ph.D.
  Professor, Division of Environmental Health Sciences
  Program Co-Leader, Carcinogenesis and Chemoprevention,
  Masonic Cancer Center
  School of Public Health
  University of Minnesota
  Minneapolis, Minnesota
- Robert A. Schnoll, Ph.D.
  Director, Center for Interdisciplinary Research on Nicotine Addiction,
  Department of Psychiatry, Perelman School of Medicine
  Professor, Department of Psychiatry, Perelman School of Medicine
  Associate Director for Population Science, Abramson Cancer Center
  Senior Fellow, Center for Public Health Initiatives
  University of Pennsylvania
  Philadelphia, Pennsylvania
- Vani N. Simmons, Ph.D.
  Co-Director, Tobacco Research and Intervention Program
  Senior Member, Department of Health Outcomes and Behavior
  Moffitt Cancer Center
  Tampa, Florida
- Hilary A. Tindle, M.D., M.P.H.
  Associate Professor of Medicine, School of Medicine and
  Vanderbilt Ingram Cancer Center
  William Anderson Spickard Jr., M.D., Chair in Medicine
  Founding Director of ViTAL, the Vanderbilt Center for Tobacco,
  Addiction and Lifestyle
  Vanderbilt University
  Nashville, Tennessee
- Graham Warren, M.D., Ph.D.
  Professor and Mary M. Gilbreth Endowed Chair of Clinical Oncology
  Vice Chairman for Research in Radiation Oncology
  Department of Radiation Oncology
  Department of Cell and Molecular Pharmacology and
  Experimental Therapeutics
  Hollings Cancer Center
  Medical University of South Carolina
  Charleston, South Carolina

## Contributors

- Rob Adsit, M.Ed.
  Director of Education and Outreach
  Center for Tobacco Research and Intervention
  School of Medicine and Public Health
  University of Wisconsin-Madison
  Madison, Wisconsin
- Steven L. Bernstein, M.D.
  Chief Research Officer
  Dartmouth-Hitchcock Medical Center
  Senior Associate Dean for Clinical and Translational Research
  Geisel School of Medicine at Dartmouth
  Director, C. Everett Koop Institute
  Professor of Emergency Medicine
  Lebanon, New Hampshire
- Paul M. Cinciripini, Ph.D.
  Professor and Chair, Department of Behavioral Science
  Division of Cancer Prevention and Population Sciences
  University of Texas
  MD Anderson Cancer Center
  Houston, Texas
- Heather D’Angelo, Ph.D., M.H.S.
  Program Director
  Health Communication and Informatics Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Nicole Senft Everson, Ph.D.
  Program Director
  Health Communication and Informatics Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Michael T. Halpern, M.D., Ph.D., M.P.H.
  Medical Officer
  Healthcare Assessment Research Branch
  Healthcare Delivery Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Brian L. Hitsman, Ph.D.
  Associate Professor of Preventive Medicine
  Feinberg School of Medicine
  Northwestern University
  Chicago, Illinois
- Frank T. Leone, M.D., M.S.
  Professor, Medicine
  Director, Comprehensive Smoking Treatment Programs
  University of Pennsylvania, Perelman School of Medicine
  Philadelphia, Pennsylvania
- Margaret Mayer, Ph.D., M.P.H.
  Program Director
  Tobacco Control Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- LaTrice Montgomery, Ph.D.
  Research Associate Professor
  Psychiatry and Behavioral Neuroscience
  University of Cincinnati, College of Medicine
  Cincinnati, Ohio
- Mark Parascandola, Ph.D., M.P.H.
  Chief, Research and Training Branch
  Center for Global Health
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Jamie S. Ostroff, Ph.D.
  Chief, Behavioral Sciences Service and Vice Chair of Research
  Department of Psychiatry and Behavioral Sciences
  Memorial Sloan Kettering Cancer Center
  Professor of Population Health Sciences
  Weill Medical College of Cornell University
  New York, New York
- Ramzi G. Salloum, Ph.D.
  Associate Professor, Health Outcomes and Biomedical Informatics, College of Medicine
  University of Florida
  Gainesville, Florida
- Christine E. Sheffer, Ph.D.
  Professor of Oncology, Department of Health Behavior
  Roswell Park Comprehensive Cancer Institute
  Buffalo, New York
- Jamie L. Studts, Ph.D.
  Professor
  Division of Medical Oncology
  Department of Medicine
  University of Colorado School of Medicine
  Co-Leader of Cancer Prevention and Control
  University of Colorado Cancer Center
  Aurora, Colorado

## Reviewers

- Brian S. Armour, Ph.D.
  Associate Director for Science
  Office on Smoking and Health
  Centers for Disease Control and Prevention
  Atlanta, Georgia
- Julia T. Arnold, Ph.D., M.S.
  Program Director
  Translational Research Program
  Division of Cancer Treatment and Diagnosis
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- David Berrigan, Ph.D., M.P.H.
  Program Director
  Health Behaviors Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Kelly D. Blake, Sc.D.
  Program Director
  Health Communication and Informatics Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Michele Bloch, M.D., Ph.D.
  Chief, Tobacco Control Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Thomas H. Brandon, Ph.D.
  Department Chair and Program Leader, Health Outcomes and Behavior
  Moffitt Distinguished Scholar
  Director, Tobacco Research & Intervention Program
  Moffitt Cancer Center
  Professor, University of South Florida Departments of Psychology
  and Oncologic Sciences
  Tampa, Florida
- Alexandra R. Budenz, Dr.P.H., M.A.
  Social Scientist
  Office of Health Communication and Education
  Center for Tobacco Products
  Food and Drug Administration
  Silver Spring, Maryland
- Priscilla Callahan-Lyon, M.D.
  Senior Science Advisor
  Office of the Center Director
  Center for Tobacco Products
  Food and Drug Administration
  Silver Spring, Maryland
- Matthew J. Carpenter, Ph.D.
  Professor, College of Medicine, Department of Psychiatry and Behavioral Sciences
  Co-Leader, Cancer Control Program
  Hollings Cancer Center
  Medical University of South Carolina
  Charleston, South Carolina
- Frank J. Chaloupka, Ph.D.
  Distinguished Professor Emeritus
  University of Illinois Chicago
  Chicago, Illinois
- David Chambers, DPhil
  Deputy Director for Implementation Science
  Office of the Director
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Srikumar Chellappan, Ph.D.
  Moffitt Distinguished Scholar, Professor, and Chair
  Department of Tumor Biology
  Moffitt Cancer Center
  Tampa, Florida
- Joseph T. Ciccolo, Ph.D.
  Program Director
  Tobacco Control Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- JoyAnn (Rohan) Courtney, Ph.D.
  Health Scientist Administrator
  Office of Disease Prevention
  National Institutes of Health
  Bethesda, Maryland
- Elizabeth A. Courtney-Long, M.A., M.S.P.H.
  Deputy Associate Director for Science
  Office on Smoking and Health
  Centers for Disease Control and Prevention
  Atlanta, Georgia
- K. Michael Cummings, Ph.D., M.P.H.
  Professor, College of Medicine, Department of Psychiatry and Behavioral Sciences
  Department of Psychiatry and Behavioral Sciences
  Medical University of South Carolina
  Co-Leader Tobacco Research Program
  Hollings Cancer Center
  Charleston, South Carolina
- Carolyn Dresler, M.D., M.P.A.
  Volunteer, Action on Smoking and Health
  Thoracic Surgical Oncologist, Retired
  Western Colorado
- Kristie Foley, Ph.D., M.S.
  Professor and Chair, Department of Implementation Science
  Acting Senior Associate Dean for Research
  Wake Forest University School of Medicine
  Winston-Salem, North Carolina
- Neal D. Freedman, Ph.D., M.P.H.
  Senior Investigator
  Metabolic Epidemiology Branch
  Division of Cancer Epidemiology and Genetics
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Kya Grooms, Ph.D., M.P.H.
  ORISE Post-Doctoral Fellow
  Oak Ridge Institute for Science and Education
  Office on Smoking and Health
  Centers for Disease Control and Prevention
  Atlanta, Georgia
- Jaimee Heffner, Ph.D.
  Associate Professor, Cancer Prevention Program
  Public Health Sciences Division
  Fred Hutchinson Cancer Research Center
  Seattle, Washington
- Nadia Howlader, Ph.D., M.S.
  Program Director and Cancer Epidemiologist
  Data Analytics Branch
  Surveillance Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Leah Hubbard, Ph.D.
  Program Director, Brain, Skin, and Head & Neck/Thyroid Specialized Programs
  of Research Excellence Translational Research Program
  Division of Cancer Treatment and Diagnosis
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Maki Inoue-Choi, Ph.D., M.S., R.D.
  Staff Scientist
  Metabolic Epidemiology Branch
  Division of Cancer Epidemiology and Genetics
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Paul Jacobsen, Ph.D.
  Associate Director
  Healthcare Delivery Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Ron Johnson, Ph.D.
  Program Director
  DNA and Chromosome Aberrations Branch
  Division of Cancer Biology
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- William M. P. Klein, Ph.D.
  Associate Director
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Chris Kotsen, Psy.D., NCTTP
  Associate Professor of Psychology in Clinical Psychiatry
  Weill Cornell Medical College
  Associate Director, Tobacco Treatment Program
  Department of Psychiatry & Behavioral Sciences
  Memorial Sloan Kettering Cancer Center
  New York, New York
- Igor A. Kuzmin, Ph.D.
  Program Director
  Translational Research Program
  Division of Cancer Treatment and Diagnosis
  National Cancer Institute
  National Institutes of Health
  Rockville, Maryland
- Gabriel Y. Lai, Ph.D.
  Program Director
  Environmental Epidemiology Branch
  Epidemiology and Genomics Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Stephanie R. Land, Ph.D.
  Program Director and Statistician
  Tobacco Control Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Natasha Buchanan Lunsford, Ph.D., M.A.
  Associate Director for Health Equity
  Office on Smoking and Health
  Centers for Disease Control and Prevention
  Atlanta, Georgia
- Ann Malarcher, Ph.D., M.S.P.H.
  Senior Public Health Analyst
  Katmai Government Services
  Office on Smoking and Health
  Centers for Disease Control and Prevention
  Atlanta, Georgia
- Candace Maynard, M.P.A.
  Deputy Associate Director, Office of Program Management
  Branch Chief, NCI’s Cancer Information Service
  Office of Communication and Public Liaison
  National Cancer Institute
  Bethesda, Maryland
- Rachel Grana Mayne, Ph.D., M.P.H.
  Program Director
  Tobacco Control Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Steven F. Nothwehr, Ph.D.
  Program Director
  Translational Research Program
  Division of Cancer Treatment and Diagnosis
  National Cancer Institute
  National Institutes of Health
  Rockville, Maryland
- Orestis A. Panagiotou, M.D., Ph.D.
  Assistant Professor
  Department of Health Services, Policy and Practice
  Brown University School of Public Health
  Legorreta Cancer Center
  Providence, Rhode Island
- Elyse R. Park, Ph.D., M.P.H.
  Clinical Associate in Psychology
  Program Director, Cancer Center Smokefree Support Service
  Professor, Psychiatry & Medicine
  Director, Health Promotion and Resiliency Intervention Research Program
  Massachusetts General Hospital
  Harvard Medical School
  Boston, Massachusetts
- Yvonne Prutzman, Ph.D., M.P.H.
  Program Director
  Tobacco Control Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Carolyn Reyes-Guzman, Ph.D., M.P.H.
  Program Director and Epidemiologist
  Tobacco Control Research Branch
  Behavioral Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Kimber P. Richter, Ph.D., M.P.H., NCTTP
  Director, UKanQuit at the University of Kansas Hospital
  Professor, Population Health
  Co-founder, University of Kansas Tobacco Treatment Specialist Training Program
  University of Kansas School of Medicine
  Kansas City, Kansas
- Erin Rogers, Dr.P.H., M.P.H.
  Assistant Professor
  Department of Population Health
  NYU Grossman School of Medicine
  NYU Langone Health
  New York, New York
- Isabel C. Scarinci, Ph.D., M.P.H.
  Professor
  Vice-Chair for Global and Rural Health
  Department of Obstetrics and Gynecology
  Heersink School of Medicine
  Senior Advisor for Globalization and Cancer
  O’Neal Comprehensive Cancer Center
  University of Alabama at Birmingham
  Birmingham, Alabama
- Peter G. Shields, M.D.
  Deputy Director, Comprehensive Cancer Center
  Professor, Epidemiology
  College of Public Health
  The Ohio State University
  Columbus, Ohio
- Eva Szabo, M.D.
  Chief, Lung and Upper Aerodigestive Cancer Research Group
  Division of Cancer Prevention
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Kathryn L. Taylor, Ph.D.
  Professor, Department of Oncology
  Cancer Prevention and Control Program
  Lombardi Comprehensive Cancer Center
  Georgetown University Medical Center
  Washington, D.C.
- Cheryll C. Thomas, M.S.P.H.
  Deputy Associate Director for Science
  Division of Cancer Prevention and Control
  Centers for Disease Control and Prevention
  Atlanta, Georgia
- Randi Tolstyk, M.S.Ed.
  Public Health Analyst
  Office on Smoking and Health
  Centers for Disease Control and Prevention
  Atlanta, Georgia
- Emily S. Tonorezos, M.D., M.P.H.
  Director
  Office of Cancer Survivorship
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Peter Ujhazy, M.D., Ph.D.
  Deputy Associate Director
  Translational Research Program
  Division of Cancer Treatment and Diagnosis
  National Cancer Institute
  National Institutes of Health
  Bethesda, Maryland
- Brenna VanFrank, M.D., M.S.P.H.
  Medical Officer
  Office on Smoking and Health
  Centers for Disease Control and Prevention
  Atlanta, Georgia
- Robert E. Vollinger, Jr., Dr.P.H., M.S.P.H.
  Senior Policy Analyst
  Office on Smoking and Health
  Centers for Disease Control and Prevention
  Washington, D.C.

## Editorial and Publication Support

- Laura Baker, M.P.H.
  Senior Public Health Associate
  The Bizzell Group
  New Carrollton, Maryland
- Dana Chomenko, M.A., PMP
  Vice President, Public Health Research and Evaluation
  BLH Technologies, Inc.
  Rockville, Maryland
- Megan Keil, M.P.H.
  Public Health Associate
  The Bizzell Group
  New Carrollton, Maryland
- Cailey Muñana, M.P.H.
  Public Health Associate
  The Bizzell Group
  New Carrollton, Maryland
- Jenny Twesten, M.P.H.
  Managing Director, Health Research
  The Bizzell Group
  New Carrollton, Maryland
- K. Ceres Wright, M.A.
  Scientific Publications Manager/Writer–Editor
  The Bizzell Group
  New Carrollton, Maryland

The team acknowledges the editing, design, and project management support from the following:

- Lisa Adams, BLH Technologies, Inc.
- Pam Grimes, BLH Technologies, Inc.
- Terry Head, BLH Technologies, Inc.
- Sarah Ashley Jolly, BLH Technologies, Inc.
- Susan Long, The Bizzell Group
- Jolie A. Mandelbaum, BLH Technologies, Inc.
- Srila Sen, The Bizzell Group
- Stephanie Siekierka, BLH Technologies, Inc.