# Table of Abbreviations and Acronyms

Abbreviation/Acronym: Definition
AACR: American Association for Cancer Research
ASCO: American Society of Clinical Oncology
BRFSS: Behavioral Risk Factor Surveillance System
C3I: Cancer Center Cessation Initiative
CBT: Cognitive behavioral therapy
CDC: U.S. Centers for Disease Control and Prevention
EHR: Electronic health record
ENDS: Electronic nicotine delivery systems
FDA: U.S. Food and Drug Administration
IASLC: International Association for the Study of Lung Cancer
NCCN: National Comprehensive Cancer Network
NCI: U.S. National Cancer Institute
NHIS: National Health Interview Survey
NRT: Nicotine replacement therapy
USPSTF: U.S. Preventive Services Task Force