# About the National Cancer Institute Tobacco Control Monograph Series

The National Cancer Institute established the Tobacco Control Monograph series (formerly the Smoking and Tobacco Control Monograph series) in 1991. The series provides comprehensive scientific reviews of tobacco use, treatment, and prevention topics to inform the work of researchers, clinicians, and public health practitioners working to reduce cancer morbidity and mortality. All 23 Tobacco Control Monographs and their supplemental materials can be downloaded from cancercontrol.cancer.gov/monographs (https://protect-us.mimecast.com/s/Emj3CR6DEzFREpjSNZV_E?domain=cancercontrol.cancer.gov).