# Supplementary Materials

- Fact Sheet
- Presentation Slides
- Social Media Toolkit