# Parameters, Methods and Considerations for the Physicochemical Characterization of Polymeric Nanoparticles

## Size/Size Distribution

- Dynamic light scattering (DLS)
- Multi-angle light scattering (MALS)
- Laser diffraction
- Transmission electron microscopy (TEM)
- Resistive pulse sensing
- Asymmetric-flow field-flow fractionation (AF4)-MALS/DLS

Comparison of batch-mode DLS showing two peaks that are not resolved versus flow-mode DLS aided by AF4 separation, showing two clearly resolved peaks.

Batch-mode (inset) versus flow-mode DLS measurements of a micellar drug formulation. Multiple size populations are observed by both measurements and indicate a polydispersed sample. However, flow-mode DLS (coupled to AF4) can better measure the size distributions of each population. Adapted from Anal Bioanal Chem, 2020, 412(2), 425-428.

## Composition

- Drug concentration: total, free & encapsulated
- Prodrug drug content
- Drug/Prodrug loading distribution (as a function of size)
- Targeting ligand concentration
- Individual polymer concentrations
- Excipient concentrations
- Particles per mL concentration
- Osmolality, viscosity measurements

Comparison of the drug quantitation from four different techniques. All techniques show a similar amount of drug, approximately 6.5%.

Several orthogonal techniques to quantitate the percent of drug in a polymeric prodrug formulation. In this example, drug content was determined by elemental analysis (nitrogen and sulfur content), base hydrolysis followed by RP-HPLC separation with UV detection, and size exclusion chromatography coupled with multi-angle light scattering and refractive index detectors (SEC-MALS/RI). Adapted from Drug Deliv Transl Res, 2019, 9(6), 1057-1066.

## Surface Characteristics

- Zeta potential
- Protein binding assessment by AF4-MALS/DLS
- Quartz crystal microbalance with dissipation monitoring (QCM-D)

Flow-mode DLS traces for four latex bead samples with four different size PEG conjugated to the surface, shown with and without plasma incubation. Smaller PEG sizes show a shift in the overall size distribution due to protein binding upon plasma incubation. No size change is noted for larger PEG sizes.

Flow-mode DLS, coupled to AF4, of polystyrene beads conjugated to various lengths of PEG before and after incubation in human plasma. As PEG length increases, polydispersity decreases and there is minimal change in the size distribution pattern (red vs green trace), suggesting decreased protein binding with increased PEG length.

## Purity

- Drug/Prodrug impurities
- Free drug/prodrug concentration
- Polymer impurities and degradation
- Polymer functionality (end-group analysis)
- Residual solvents and reagents

SEC-MALS chromatogram showing the change in overall size distribution for monomer and dimer populations.

Purity assessment of drug-conjugated and targeted Generation 5 PAMAM dendrimers by size exclusion chromatography with MALS and refractive index detectors in-line (SEC-MALS-RI). The molecular mass distribution and polydispersity for the monomer and dimer are based on the bracketed molar mass distribution.

## Batch-to-Batch Consistency

- Assessed by choosing relevant parameters (i.e., lot release criteria) that relate to a desired in vivo outcome

Representative SEC-MALS, HPLC, MALDI TOF and titration spectra for G5 amine terminated dendrimers. Accompanying table shows the purity, molecular weight, zeta potential and number of surface amines for 13 different batches.

Batch-to-batch consistency for G5 amine-terminated dendrimers was assessed by several techniques. In this case, HPLC and titration were the relevant characterization methods.

## Stability

- Size/Size distribution; aggregation
- Drug leakage and degradation
- Polymer degradation
- Drug/prodrug release in plasma
- Solvent, thermal, pH, photo, freeze-thaw, lyophilization, centrifugation, filtration
- Storage conditions/shelf-Life

HPLC traces showing the decrease in the prodrug peak over time and increase in the void peak. The peak areas were used to calculate the half life of the prodrug in plasma.

Stability assessment of prodrug micelles in the presence of human plasma. The hydrolysis of the intact prodrug was measured by RP-HPLC and used to construct a hydrolysis versus time graph, which can be used to determine t½.

## Starting Material Characterization

- Drug/prodrug identity (structure)
- Drug/prodrug purity (degradation products)
- Polymer composition (molecular mass and polydispersity)
- Polymer purity and functionality
- Storage conditions/shelf life

SEC-MALS spectra showing the molar mass distribution of mPEG-PLGA nanoparticles.

Polymer composition and molar mass distribution of mPEG-PLGA were determined by thermogravimetric analysis and SEC-MALS-RI (above), respectively.

## Morphology

- Transmission electron microscopy (TEM)

Electron micrograph showing micellar nanoparticle and contaminating smaller micelles from an excipient in the formulation.

Representative TEM image of PEGylated oil-filled prodrug nanocapsules. In addition to determining the size distribution, TEM can be used to evaluate morphology and purity. Here, the presence of residual surfactant forming smaller micelles are observed in the background.

## Relevant NCL Publications

Anal Bioanal Chem, 2020, 412(2), 425–428. PMID: 3177663931776639
J Control Release, 2019, 299, 31–43. PMID: 3079786830797868
Pharmaceutical Research, 2019, 37, 6. PMID: 3182854031828540
Drug Deliv Transl Res, 2019, 9(6), 1057–1066. PMID: 3111952131119521
Methods in Molecular Biology, Vol. 1628, 2018, p. 49–55. PMID: 2903909229039092
Methods in Molecular Biology, Vol. 1628, 2018, p. 57–63. PMID: 2903909329039093
Anal Bioanal Chem, 2017, 409(24), 5779–5787. PMID: 2876206628762066
Polymer nanoparticles: A Guide for Design, Preparation and Development as Nanomedicines, 2016, 187–203. ISBN: 978-3-319-41421-8
Anal Bioanal Chem, 2015, 407(29), 8661–8672. PMID: 2644984526449845