# NCL Method STE-1.3 Detection and Quantification of Gram-Negative Bacterial Endotoxin Contamination in Nanoparticle Formulations by Gel-Clot LAL Assay

Version 3.1

## 1 Introduction

This document discusses the quantitative detection of Gram-negative bacterial endotoxin in nanoparticle preparations using the gel-clot Limulus Amebocyte Lysate (LAL). The protocol for this assay is based on instructions provided with the reagents from Associates of Cape Cod as well as the USP standard 85 “Bacterial endotoxin test” [1]. In lieu of detailing the exact procedure here (which can be found in reference [1], a “Bench Sheet” is provided that can be used in conjunction with the USP protocol.

## 2 Principles

Gram negative bacterial endotoxin reacts with an enzyme in the Limulus Amebocyte Lysate which results in activation of a proteolytic cascade leading to clotting of the lysate. The concentration of endotoxin in a sample is determined by sample titration to an endpoint.

## 3 Reagents, Materials, and Equipment

Note: The NCL does not endorse any of the suppliers listed below; these reagents were used in the development of the protocol and their inclusion is for informational purposes only. Equivalent supplies from alternate vendors can be substituted. Please note that suppliers may undergo a name change due to a variety of factors. Brands and part numbers typically remain consistent but may also change over time.

3.1 Reagents
  3.1.1 Test nanomaterial
  3.1.2 Sodium Hydroxide (NaOH) (Sigma, S2770)
  3.1.3 Hydrochloric acid (HCl) (Sigma, H9892)
  3.1.4 Control Endotoxin Standard (Associates of Cape Cod (ACC), E0005)
  3.1.5 LAL Reagent (ACC, G5003)
  3.1.6 LAL grade water (ACC, WP0501)
3.2 Materials
  3.2.1 Pipettes, 0.05 to 10 mL
  3.2.2 Microcentrifuge tubes, 1.5 mL
  3.2.3 Disposable endotoxin-free glass dilution tubes, 12x75 mm (ACC, TB0240)
  3.2.4 Gel-clot test tubes (ACC, TS050)
3.3 Equipment
  3.3.1 Microcentrifuge
  3.3.2 Refrigerator, 2-8°C
  3.3.3 Freezer, −20°C
  3.3.4 Vortex
  3.3.5 Water bath (important to use a non circulating bath)
  3.3.6 tube racks

## 4 Reagent Preparation

4.1 [underlined: Sodium Hydroxide]
  Prepare from concentrated stock by dilution into pyrogen-free LAL reagent water to make a 0.1 N final concentration solution.
4.2 [underlined: Hydrochloric Acid]
  Prepare from concentrated stock by dilution into pyrogen-free LAL reagent water to make a 0.1 N final concentration solution.

## 5 Preparation of Study Samples

Study samples should be reconstituted in either LAL reagent water or sterile, pyrogen-free PBS. The pH of the study sample should be checked using a pH microelectrode and adjusted, if necessary, within the range of 6.0-8.0 using either sterile NaOH or HCl. Do not adjust the pH of unbuffered solutions. To avoid sample contamination from microelectrode, always remove a small aliquot of the sample for use in measuring the pH. If the sample was prepared in PBS, blank PBS should also be tested in the assay.

The concentration of nanomaterial is unique to each formulation. The goal of this test is to measure endotoxin level per mg of the test formulation, which commonly refers to the active pharmaceutical ingredient (API) but may also be measured in mg of total formulation or total element (e.g. gold or silver). The sample should be tested from the stock using several dilutions that do not exceed the Maximum Valid Dilution (MVD).

To determine the MVD one needs to know three parameters: endotoxin limit (EL), sample concentration and assay sensitivity (λ). The EL is calculated according to the following formula:

EL = K / M

where K is maximum endotoxin level allowed per dose (5 EU/kg for all routes of administration except for the intrathecal route, for which K is 0.2 EU/kg) and M is the maximum dose to be administered per kg of body weight per single hour [1]. Note, estimation of EL for nanomaterials used as radiopharmaceuticals or as medical devices will be different; please refer to USP BET 85 for details [1]. When the dose information for the test nanomaterial is available based on an animal model (e.g. in mouse), one may use it to convert into human equivalent dose (HED). To do so, the animal dose is divided by the conversion factor specific to each animal species, e.g. 12.3 for mouse. Please refer to the FDA guideline for other conversion ratios [2]. Dose for cancer therapeutics is often provided in mg/m^2^ instead of mg/kg. To convert an animal or human dose from mg/m^2^ to mg/kg the dose in mg/kg is divided by the conversion factor of 37, indicated as k_m_ (for mass constant). The k_m_ factor has units of kg/m^2^; it is equal to the body weight in kg divided by the surface area in m^2^. Example 74 mg/m^2^/37 = 2mg/kg [2].

The MVD is determined according to the following formula:

MVD = ( EL × sample concentration ) / λ

For example, when nanoparticle sample concentration is 10 mg/mL and its maximum dose in mouse is 123 mg/kg, the HED is 123/12.3 = 10mg/kg. The EL for all routes except intrathecal would be 0.5 EU/mg (5EU/kg/10mg/kg) and MVD would be 166.7 ((0.5 EU/mg × 10 mg/mL)/0.03 EU/mL). In this case, the nanomaterial will be tested directly from stock and at several dilutions not exceeding 166.7, e.g. 5, 75 and 150 (or 166). When the information about the dose is unknown, the highest final concentration of the test nanomaterial is 1 mg/mL and the MVD is 16.7. It is very important to recognize that if the dose, route of administration and/or the sample concentration for the test nanomaterial change, the EL and MVD will also change.

## 6 Procedure

6.1 Overview
  The gel clot LAL procedure described here follows the USP BET 85 protocol. For complete details on this procedure, please consult the USP reference [1]. Outlined below is a “Bench Sheet” that can be printed and used alongside the USP protocol.
  Briefly, the test includes three steps:
  Step 1 Confirmation of Labeled Lysate Sensitivity
  Step 2 Test for Interfering Factors
  Step 3 Endotoxin assessment in the test sample by either limit test or quantitative test
  Step 1 can be done once and need not to be repeated until bacterial endotoxin standard and lysate lots have changed. Step 2 analysis is conducted to identify any potential interference of the test sample with the LAL gel-clot procedure. The qualitative (limit test) or quantitative test of Step 3 is done only after absence of interference has been confirmed in Step 2.
  The qualitative (limit) test results are negative if both replicates did not clot. If clotting was observed in one replicate the test has to be repeated. If in the repeated test one or both replicates clotted, the sample contains endotoxin contamination at a level equal to or more than the assay sensitivity. If a diluted sample was tested, the assay sensitivity must be multiplied by the dilution factor to report the limit of endotoxin contamination in the sample.
  The quantitative test determines endotoxin concentration in the sample as endpoint concentration of the replicates with a positive response (i.e., clotting). If none of the replicates of the valid assay give a positive response, the concentration of endotoxin is reported as that below the lysate sensitivity. If all replicates are positive, then the concentration of endotoxin is reported as greater than or equal to that of the greatest dilution multiplied by the assay sensitivity.
6.2 General Procedure
  6.2.1 Label as many reaction tubes as needed to accommodate the number of analyzed test samples. Refer to the bench sheet for details about the number of replicates used in step 1, step 2 and step 3 of the assay.
  6.2.2 Aliquot 100 μL of water, controls or test sample per tube.
  6.2.3 Prepare CSE such as the final concentration is equal to 4λ. When 100 μL of this standard is combined with 100 μL of water or test sample, the final concentration of CSE is equal to 2λ.
  6.2.4 Add 100 μL of lysate per test tube, vortex briefly, then place entire rack into a water bath set to 37 °C for 1 hr.
  6.2.5 Remove samples from water bath and dry using paper towel.
  6.2.6 Invert the tube using smooth motion and record results using “+” (firm clot) or “-” (no clot or loose clot) on the bench sheet.
  6.2.7 Proceed with analysis according to the USP BET 85; use bench sheet as supporting material.

### Step 1 Qualification of Reagent Sensitivity (Perform once with each new reagent lot)

#### 1 Information About Test

Incubation Time | Start: | Finish:
Temperature | Start: | Finish:

Date ________________________ Tested by ________________________.

#### 2 Test Results

Record test results into the table below. If a firm gel has formed that remains in place under inversion, the result is “+” (or positive). If an intact gel is not formed the result is “-” (or negative).

Replicate Number | Endotoxin Standard Concentration, EU/mL
Replicate Number | 2λ | 1λ | 0.5λ | 0.25λ | Water
1
2
3
4

The test is valid if the lowest concentration of the tested standard solutions is negative in all replicates. Please check here to confirm this is the case____________.

#### 3 Calculation of Geometric Mean Sensitivity (Reagent Qualification)

The endpoint is the smallest concentration in the series of decreasing concentrations of CSE that clots the lysate.

Geometric Mean Endpoint Concentration = Antilog ( Σe / f )

where ∑e is the sum of the log end-point concentrations of the dilution series used, and f is the number of replicate test tubes. The Geometric Mean Endpoint Concentration = λ or assay sensitivity. Please enter λ value calculated in this section into the far-right column of the table in section 4 below.

#### 4 Reagent Qualification Summary

Reagents | Lot # | Expiration | Sensitivity, EU/mL
Pyrotell
Endotoxin Standard | | | N/A
Water | | | N/A

### Step 2 Inhibition Enhancement Control

Important Note: This step should be repeated for each nanoparticle concentration. Ideally undiluted sample is tested first. If interference is found for undiluted sample, repeat step 2 with as many dilutions as necessary to overcome the interference, but make sure the dilution does not exceed the MVD.

#### 1 Information About Test

Incubation Time | Start at: | Finish at:
Temperature | Start at: | Finish at:

Date ________________________ Tested by ________________________.

#### 2 Test Samples

Please enter EL_______________EU/mg and MVD________________

*Nanoparticles are from stock______or at initial dilution______or MVD________Nanoparticle stock concentration_________mg/mL by API______total_______other______Concentration is based on client’s data_________or NCL PCC__________

To prepare samples B1 and C1, spike CSE at a final concentration 2λ into nanoparticles and LAL water, respectively. Next, perform three serial 1:2 dilutions of B1 and C1 in nanoparticle solution (samples B2-B4) and water (samples C2-C4), respectively. Refer to the table below for information about sample name, dilution factor, number of replicates and endotoxin concentration. The replicate here refers to one test tube.

Sample | Sample Description | Number of Replicates | Dilution Factor | Endotoxin Concentration
A | Nanoparticle solution* | 4 | none | -
B1 | CSE in nanoparticle solution* | 4 | 1 | 2 λ
B2 | CSE in nanoparticle solution* | 4 | 2 | 1 λ
B3 | CSE in nanoparticle solution* | 4 | 4 | 0.5 λ
B4 | CSE in nanoparticle solution* | 4 | 8 | 0.25 λ
C1 | CSE in LAL water | 2 | 1 | 2 λ
C2 | CSE in LAL water | 2 | 2 | 1 λ
C3 | CSE in LAL water | 2 | 4 | 0.5 λ
C4 | CSE in LAL water | 2 | 8 | 0.25 λ
D | LAL water | 2 | none | -

#### 3 Record Test Results in the Table Below

Sample | Replicate 1 | Replicate 2 | Replicate 3 | Replicate 4
A
B1
B2
B3
B4
C1
C2
C3
C4
D

#### 4 Analysis and Interpretation

Calculate geometric mean sensitivity of sample B and C using formula described in Section 3 of Step 1. Record the data below:

Sample B: ____________ EU/mL

Sample C: ____________ EU/mL

Using data from the above table (see section 3 of step 2) and calculation of geometric mean sensitivity to confirm the following points:

The test result of sample A is negative_____________

The test result of sample D is negative_____________

The test result of sample C confirms the assay sensitivity_____________.

- If the answer to all these points is yes, the test is valid_____________ (please check to confirm)
- If A is positive, the nanoparticle test sample interferes with the assay and the test is invalid________ (please check to confirm)

The sensitivity of the lysate determined in the presence of nanoparticles (sample B) is not less than 0.5λ and not more than 2λ______________

- If the answer to this point is yes, the nanoparticle test sample at the tested concentration does not contain substances interfereing with the gel-clot LAL__________(please check to confirm)
- If the answer to this point is no, the nanoparticle test sample interferes with LAL_______(please check to confirm)

If the test is valid proceed to Step 3A or 3B. Choice between 3A and 3B depends on the project need.

### Step 3A Limit Test

Important Note: This test is done at the highest nanoparticle concentration (lowest dilution of the stock nanoparticle sample) not interfering with gel-clot LAL. Refer to Step 2 for information about this concentration.

#### 1 Information About Test

Incubation Time | Start: | Finish:
Temperature | Start: | Finish:

Date ________________________ Tested by ________________________.

#### 2 Record Test Results in the Table Below

*Nanoparticles are from stock______or at dilution______or at MVD________Nanoparticle stock concentration_________mg/mL by API______total_______other______Concentration is based on client’s data_________or NCL PCC__________

Sample | Sample Description | Dilution Factor | Endotoxin Conc. | Replicate 1 | Replicate 2
A | Nanoparticles* | | -
B | 2 λ in Nanoparticles* | | 2 λ
C | 2 λ LAL water | | 2 λ
D | LAL water | | -

#### 3 Analysis and Interpretation

Using data from the above table (see section 2 of step 3A) confirm the following points:

- Both replicates of sample B are positive_____________
- Both replicates of sample C are positive _____________
- Both replicates of sample D are negative _____________

If the answer to all these points is yes, the test is valid_____________(please check to confirm)

- Both replicates of sample A are negative_______= nanoparticle complies with the test
- Both replicates of sample A are positive _______= nanoparticle does not comply with the test
- One replicate of sample A is positive__________= repeat test one more time
- Both replicates of sample A in repeat test are negative_______= nanoparticle complies with the test;
- One or both replicates of sample A in repeat test is positive__________= nanoparticle does not comply with the test.

### Step 3B Quantitative Test

Important Note: This test is done at the highest nanoparticle concentration (lowest dilution of the stock nanoparticle sample) not interfering with gel-clot LAL. This dilution is called “initial dilution”. Refer to Step 2 for information about this concentration.

#### 1 Information about Test

Incubation Time | Start: | Finish:
Temperature | Start: | Finish:

Date ________________________ Tested by ________________________.

#### 2 Record Test Results in the Table Below

Sample | Sample Description | Dilution Factor | Endotoxin Conc. | Replicate 1 | Replicate 2
A1 | Nanoparticles^*^ | 1 | -
A2 | Nanoparticles^*^ | 2 | -
A3 | Nanoparticles^*^ | 4 | -
A4 | Nanoparticles^*^ | 8 | -
B | Nanoparticles^*^ +2λ endotoxin Std | 1 | 2λ
C1 | Water+ 2λ endotoxin Std | 1 | 2λ
C2 | Water+ 1λ endotoxin Std | 2 | 1λ
C3 | Water+ 0.5λ endotoxin Std | 4 | 0.5λ
C4 | Water+ 0.25λ endotoxin Std | 8 | 0.25λ
D | Water | - | -

* The concentration of nanoparticles in this sample is the one selected in part 2. For purposes of this test, it is called “initial dilution”; subsequent dilutions of the initial dilution should be done in a way such as the final dilution not exceeding the MVD. For example, if the MVD is 166.7 and the initial dilution of nanoparticles to a concentration not interfering with the LAL is 20, analysis of this sample at dilutions shown in the dilution factor column is within the MVD. Likewise, if the initial dilution is 40, then subsequent dilution 8 will be above the MVD.

#### 3 Result Evaluation

3.1 Calculate geometric mean end point concentration for sample C according to formula described in Section 3 of Step 1. Use the table in section 3.2 to record observations.
3.2 Test is valid if all of the following conditions are met:
  Condition | Yes (+)
  Both replicates of sample D are negative
  Both replicates of sample B are positive
  The geometric mean endpoint concentration of sample C is between 2λ and 0.5λ
3.3 Calculate endotoxin concentration in nanoparticle sample (Sample A):
  3.3.1 Calculate the endpoint concentration for each replicate by multiplying each endpoint dilution factor by λ. Record results in the table below.
    Dilution Factor | Endpoint Concentration, EU/mL
    1 | λ × 1 =
    2 | λ × 2 =
    4 | λ × 4 =
    8 | λ × 8 =
  3.3.2 Consider the following points:
    - The endotoxin concentration of the nanoparticle solution is the endpoint concentration of the replicates. The endpoint concentration is the lowest concentration in the series of decreasing concentrations of CSE that clots the lysate.
    - If the test is conducted with diluted sample, the endotoxin concentration in the stock nanoparticle is the endpoint concentration multiplied by the dilution factor used to prepare intermediate dilution analyzed in the assay.
    - Record endpoint concentration here___________ × dilution factor = ____________EU/mg
    - If none of the dilutions of the test sample is positive in a valid assay, report the endotoxin concentration as < λ______________________
    - If diluted sample was analyzed, report concentration as < λ × lowest dilution factor____________
    - If all dilutions are positive, the endotoxin concentration is ≥ λ × initial dilution factor × 8 _______________

## 7 References

1 USP 34-NF29. <85>. Bacterial Endotoxins. Rockville, MD: United States Pharmacopeia, 2011, Volume 1, 78–81.
2 FDA Guidance for Industry and Reviewers Estimating the Safe Starting Dose in Clinical Trials for Therapeutics in Adult Healthy Volunteers. December 2002.
3 US FDA. Guidance for Industry. Pyrogen and Endotoxins testing: Questions and answers, 2012.

## 8 Abbreviations

API: active pharmaceutical ingredient
EU: endotoxin unit
EL: endotoxin limit
BET: bacterial endotoxin test
CSE: control standard endotoxin
HED: human equivalent dose
FDA: Food and Drug Administration
IEC: inhibition/enhancement control
LAL: Limulus Amebocyte Lysate
MVD: maximum valid dilution
PCC: physicochemical characterization
USP: United States Pharmacopeia