# NCL Method ITA-27 Multiplex Enzyme-Linked Immunosorbent Assay (ELISA) for Detection of Human Cytokines in Culture Supernatants

Version 1

## 1 Introduction

Cytokines, chemokines and interferons (IFN) are soluble mediators of inflammation and a variety of responses that orchestrate both innate and adaptive immunity in health and disease [1–10]. Understanding the induction of these biomarkers in response to a drug product helps to establish the product’s safety profile and shed light on the mechanism of action or mechanism of toxicity. This document describes experimental procedure for analysis of culture supernatants by multiplex ELISA to detect presence of type I IFNs (IFNα, IFNβ, IFNω), type II IFN (IFNγ), type III IFN (IFNλ), cytokines and chemokines (IL-1α, IL-1β, IL-2, IL-4, IL-5, IL-6, IL-7, IL-8, IL-10, IL-12p70, IL-13, IL-15, IL-17, IL-21, IL-22, IL-23, IL-27, IP-10, MCP-1, MCP-2, MIP-1α, MIP-1β, RANTES, TNFα) in culture supernatants. NCL protocol ITA-10 should be referred to for details of preparation of culture supernatants. Protocols for single-plex ELISA (ITA-22, ITA-23, ITA-24 and ITA-25) can also be considered. The advantage of this protocol over single-plex ELISA is that it allows simultaneous analysis of a broad spectrum of markers.

## 2 Principle

A 96-well plate is coated with capture antibodies specific to the target cytokines and immobilized at particular location within each well. Cell culture supernatants are loaded onto the plate and cytokines present in the supernatant are captured by the antibodies. The excess sample is washed away, and captured cytokines are detected with secondary antibody conjugated to biotin. Streptavidin-conjugated horse radish peroxidase is then used to detect captured analytes. After additional wash, the conjugate remaining at each location is detected using chemiluminescent substrate. Images are taken using Quansys Image Pro reader and analyzed using Q-View Software. The intensity of the individual spot corresponding to a particular analyte is proportional to the level of the analyte in the test supernatant. The quantities of the individual cytokines are determined by comparing the intensity of spots corresponding to each of the cytokines in the test sample to that in the standard curve comprised of various concentrations of reference standards. The ELISA procedure described herein takes approximately 6 hours to complete. If ELISA cannot be conducted immediately after incubation of whole blood/PBMC with nanoparticles is complete, the culture supernatants can be stored at −80°C.

## 3 Reagents, Materials, and Equipment

Note: The NCL does not endorse any of the suppliers listed below; these reagents were used in the development of the protocol and their inclusion is for informational purposes only. Equivalent supplies from alternate vendors can be substituted. Please note that suppliers may undergo a name change due to a variety of factors. Brands and part numbers typically remain consistent but may also change over time.

3.1 Reagents
  3.1.1 Custom Multiplex kit, (Quansys, 107749GR-Q-Plex^™^ Custom Chemi Kit)
  3.1.2 Phosphate buffered saline (PBS), (GE Life Science, SH30256.01)
  3.1.3 Cell culture grade water, GE Life Science, SH30529.02)
  3.1.4 RPMI1640, (GE Life Sciences, Hyclone, SH30096.01)
  3.1.5 Pen/Strep solution, (GE Life Sciences, Hyclone, SV30010)
  3.1.6 Cytokine Calibration Standards (see section 10 for the example of Product Information Card showing individual cytokine’s concentrations)
3.2 Materials
  3.2.1 96-well, U-bottom plates
  3.2.2 96-well, V-bottom polypropylene plates
  3.2.3 Pipettes covering the range from 0.05 to 1 mL
  3.2.4 Microcentrifuge tubes, 1.5 mL
  3.2.5 Multichannel pipette (8 or 12-channels)
  3.2.6 Reagent reservoirs
3.3 Equipment
  3.3.1 Microcentrifuge
  3.3.2 Refrigerator, 2-8°C
  3.3.3 Freezer, −80°C
  3.3.4 Vortex
  3.3.5 Plate shaker
  3.3.6 Plate washer
  3.3.7 Multiplex ELISA plate reader capable of reading chemiluminescence

## 4 Preparation of Reagents and Controls

4.1 Calibrators
  The kits come with 1 to 3 vials of lyophilized calibrators depending on the format being used. Each set of calibrators should be prepared with sample diluent according to the product information card included with the kit (see section 10). The calibrators will then be serially diluted, 3-fold, as described in the procedure below (see step 6.3).
4.2 Sample diluent (10 mL): Use as is.
4.3 Assay diluent (lyophilized): Reconstitute with 6 mL Cell Culture Grade water.
4.4 Detection reagent (lyophilized): Reconstitute with 6 mL Cell Culture Grade water.
4.5 Streptavidin-HRP (6 mL): Use as is.
4.6 Substrate A (3 mL) and Substrate B (3 mL): Mix both reagents together 15 minutes before use and store in the dark at room temperature.
4.7 Wash buffer, 20X (50 mL): Mix with 950 mL of distilled water for a 1X solution.

## 5 Preparation of Inhibition/Enhancement Controls (IECs)

Two approaches can be used to prepare IECs:

5.1 [underlined: Approach A]
  Use culture supernatant from the positive control sample and spike it with the test nanoparticle at 4 concentrations (refer to NCL ITA-10). For example, add 6 μL of 10X nanoparticle working solution into 60 μL of positive control supernatant. The final concentration of nanoparticle in this sample will mimic that in the supernatants from nanoparticle treated cells. The concentration of the analyte in the IEC supernatant will be 1.1X lower. Compare the analyte level in the positive control supernatant with that in IEC x 1.1 to account for the dilution factor. If the difference in test results is within 25%, testnanoparticle does not interfere with ELISA.
5.2 [underlined: Approach B]
  Use cell free controls and spike them with calibration standard. For example, add 6 μL of calibrator 1 from step 6.3 to 60 μL of cell-free supernatant from ITA-10. This IEC should be approximately comparable to calibrator 3 (step 6.3.3). If the difference in test results is within 25%, test-nanoparticle does not interfere with ELISA.

## 6 Experimental Procedure for 4-plex Interferon Multiplex

6.1 Prepare assay diluent, sample diluent and wash buffer as described in Section 4. Store all buffers at room temperature and use on the same day as preparation.
6.2 Reconstitute calibrator(s) with sample diluent according to the included information card (see Section 10 for an example information card).
6.3 Prepare calibration standards in microtubes or a 96-well tray as follows:
  6.3.1 Add 200 μL of the stock calibrator to the first tube/well labeled Standard or Calibrator 1.
  6.3.2 Add 120 μL of the sample diluent to an additional 7 tubes/wells labeled sequentially as Standard or Calibrator 2 through 8.
  6.3.3 Perform a serial, 3-fold dilution of the first standard by transferring 60 μL of the Standard 1 to the Standard 2 tube/well, mix by repeated up-and-down pipetting, continue transferring 60 μL serially into the next tubes/wells until Standard 7 is reached. Standard 8 is sample diluent only (see image below).
6.4 Thaw frozen culture supernatants at room temperature or use freshly collected supernatants.
6.5 Dilute culture supernatants 2-fold with sample diluent by mixing 60 μL of the culture supernatants with 60 μL of the sample diluent.
6.6 Add 50 μL of the assay diluent to each well on the multiplex ELISA plate.
6.7 After adding the assay diluent, load 50 μL of the standards (step 6.3) and culture supernatants (step 6.5) to the 96-well multiplex plate, seal and incubate at room temperature on a shaker set at approximately 500 rpm for 2 hours.
6.8 Wash the plate 3 times with the wash buffer prepared in step 6.1 (section 4.7). Use 300 μL of the wash buffer per well. Tap the plate on paper towel to remove excess buffer and immediately proceed to the next step.
6.9 Add 50 μL per well of previously prepared detection reagent (section 4.4), seal and incubate the plate at room temperature on a shaker set to approximately 500 rpm for 1 hour.
6.10 Repeat step 6.8.
6.11 Add 50 μL per well of the ready-to-use Streptavidin-HRP conjugate provided with the kit, seal and incubate the plate at room temperature on a shaker set to approximately 500 rpm for 15 minutes.
6.12 Repeat step 6.8 two times and immediately proceed to the next step.
6.13 Add 50 μL per well of the previously prepared ChemiLum substrate (section 4.6).
6.14 Read the plate using the Quansys ImagePro reader.

test tubes showing serial dilution

## 7 Experimental Procedure for 14-plex and 15-plex multiplex

The procedure for both the 14-plex and 15-plex is the same as the IFN 4-plex, with the exception that in [underlined: the 15-plex there is no assay buffer] as in step 6.6.

## 8 Acceptance Criteria

8.1 The % CV and PDFT for each calibration standard and quality control should be within 25%.
8.2 The % CV for each test sample, including supernatants from whole blood cultures treated with positive control, negative control and nanoparticle samples, should be within 25%. At least one replicate of positive and negative control should be acceptable for run to be accepted.
8.3 If both replicates of positive control or negative control fail to meet acceptance criterion described in 8.2 the run should be repeated.
8.4 Within the acceptable run, if two of three replicates of unknown sample fail to meet acceptance criterion described in 8.2, this unknown sample should be re-analyzed.

## 9 Example of ELISA Plate Template

Rows G & H do not contain cells.

Std: standard; B0 = blank (assay diluent); Unt: Untreated supernatant; NC: negative control supernatant; PC: positive control supernatant; VC: vehicle control supernatant; TS1-4: test sample supernatants at concentrations 1-4; IEC1-4: inhibition enhancement controls for TS1-4 concentrations; CF: cell free

## 10 Example of Product Information Card

Picture of a product information card. Provides information such as analyte, concentration, product codes, lot numbers.

## 11 References

1 Bioanalytical Chemistry of Cytokines-A Review. Julie A. Stenken, Andreas J. Poschenrieder. Anal Chim Acta. Anal Chim Acta. 2015 Jan 1; 853: 95–115. doi: 10.1016/j.aca.2014.10.009 PMCID: PMC4717841
2 IL-1 and related cytokines in innate and adaptive immunity in health and disease. Alberto Mantovani, Charles A. Dinarello, Martina Molgora, Cecilia Garlanda. Immunity. 2019 Apr 16; 50(4): 778–795. doi: 10.1016/j.immuni.2019.03.012 PMCID: PMC7174020 30995499
3 Th1 cytokines, true functional signatures for protective immunity against TB? Gucheng Zeng, Guoliang Zhang, Xinchun Chen. Cell Mol Immunol. 2018 Mar; 15(3): 206–215. doi: 10.1038/cmi.2017.113 PMCID: PMC5843617 29151578
4 Inflammation and Pancreatic Cancer: Focus on Metabolism, Cytokines, and Immunity. Andrea Padoan, Mario Plebani, Daniela Basso. Int J Mol Sci. 2019 Feb; 20(3): 676. doi: 10.3390/ijms20030676 PMCID: PMC6387440 30764482
5 Innate cell communication kick-starts pathogen-specific immunity. Amariliz Rivera, Mark C. Siracusa, George S. Yap, William C. Gause. Nat Immunol. 2016 Mar 22; 17(4): 356–363. doi: 10.1038/ni.3375 PMCID: PMC4949486 27002843
6 Cytokines: Names and Numbers You Should Care About. Stephen R. Holdsworth, Poh-Yi Gan. Clin J Am Soc Nephrol. 2015 Dec 7; 10(12): 2243–2254. doi: 10.2215/CJN.07590714 PMCID: PMC4670773 25941193
7 The immunobiology of the Interleukin-12 family: Room for discovery. Elia D. Tait Wojno, Christopher A. Hunter, Jason S. Stumhofer. Immunity. 2019 Apr 16; 50(4): 851–870. doi: 10.1016/j.immuni.2019.03.011 PMCID: PMC6472917 30995503
8 Innate control of adaptive immunity: Beyond the three-signal paradigm. Aakanksha Jain, Chandrashekhar Pasare. J Immunol. 2017 May 15; 198(10): 3791–3800. doi: 10.4049/jimmunol.1602000 PMCID: PMC5442885 28483987
9 Cytokines and Long Noncoding RNAs. Susan Carpenter, Katherine A. Fitzgerald. Cold Spring Harb Perspect Biol. 2018 Jun; 10(6): a028589. doi: 10.1101/cshperspect.a028589 PMCID: PMC5983188 28716885
10 Th17 cytokines in mucosal immunity and inflammation. Lokesh Guglani, Shabaana A. Khader. Curr Opin HIV AIDS. 2010 Mar; 5(2): 120–127. doi: 10.1097/COH.0b013e328335c2f6 PMCID: PMC2892849 20543588

## 12 Abbreviations

B0: blank (assay diluent)
CF: cell free
IEC: inhibition enhancement control
IFN: interferon
LLD: lower limit of detection
LPS: lipopolysaccharide
NC: negative control supernatant
PBMC: peripheral blood mononuclear cells
PBS: phosphate buffered saline
PC: positive control supernatant
PHA-M: phytohemagglutinin-M
Std: standard
TS: test sample supernatant
ULD: upper limit of detection
VC: vehicle control supernatant