# NCL Method GTA-14 Hep G2 Hepatocarcinoma Homogeneous Apoptosis Assay

Version 1.2

## 1 Introduction

This protocol describes the monitoring of nanoparticle treated human hepatocarcinoma cells (HepG2) for apoptosis, as part of the in vitro NCL preclinical characterization cascade (1, 2). The protocol utilizes a fluorescent method to measure Caspase-3/7 activation. This is a homogeneous assay that does not require cell isolation, as required for HepG2 Hepatocarcinoma Apoptosis Assay (NCL Method GTA-6).

## 2 Principles

Caspase-3/7 Homogeneous Fluorometric Assay:

Apoptosis in mammalian cells is initiated by activation of the Caspase family of cysteine proteases. This assay quantifies Caspase-3/7 activation in vitro by measuring the cleavage of the non-fluorescent substrate Z-DEVD-R110 (rhodamine 110, bis-(N-CBZ-L-aspartyl-L-glutamyl-L-valyl-L-aspartic acid amide)) to free rhodamine 110, which emits green fluorescence (λ_max_ = 521 nm) (3). This free rhodamine 110 is measured using a microtiter plate reader.

## 3 Reagents, Materials, Cell Lines, and Equipment

Note: The NCL does not endorse any of the suppliers listed below; their inclusion is for informational purposes only. Equivalent supplies from alternate vendors can be substituted.

3.1 Reagents
  3.1.1 Acetaminophen (APAP) (Sigma, A7085)
  3.1.2 RPMI 1640 (Hyclone, SH30096.01)
  3.1.3 L-glutamine (Hyclone, SH30034.01)
  3.1.4 Fetal Bovine Serum (Hyclone, SH30070.03)
  3.1.5 Nanoparticle
  3.1.6 Apo-ONE® Homogeneous Caspase-3/7 Assay Kit (Promega, G7790)
3.2 Materials
  3.2.1 Costar 96 well flat bottom cell culture plates (Costar, 3598)
3.3 Cell Lines
  3.3.1 HepG2 (human hepatocarcinoma cells) (ATCC, HB-8065)
3.4 Equipment
  3.4.1 Plate reader (Safire^2^–Tecan or equivalent)
  3.4.2 Plate Shaker

## 4 Reagent and Control Preparation

4.1 Positive control
  4.1.1 Acetaminophen (APAP) positive control: Add 8 mg to a total volume of 5 mL RPMI 1640 cell culture media (with 2 mM L-glutamine and 10% FBS) to make a 10 mM solution. Sterile filter using a 0.2 µm filter.
4.2 Solutions to make up fresh for each run (can be stored at 4°C for 24 h)
  4.2.1 Retrieve Apo-ONE® Assay kit from −20°C.
  4.2.2 Thaw the 100X substrate and buffer to room temperature.
  4.2.3 Mix by inversion or vortexing. Dilute substrate 1:100 in buffer.
  4.2.4 Apo-ONE® Reagent is light sensitive; store protected from light.

## 5 Experimental Procedure

5.1 Cell Preparation (or as recommended by supplier)
  5.1.1 Harvest cryopreserved cells from prepared flasks (limit to 20 passages) (Figure 1).
  5.1.2 Count cell concentration using a coulter counter or hemocytometer.
  5.1.3 Dilute cells to a density of 2.0 × 10^5^ cells/mL in RPMI 1640 cell culture media (2 mM L-glutamine, 10% FBS).
  5.1.4 Plate 100 µL/well of diluted cells as per plate format (see Appendix) for each 96 well plate (2 particles/96 well plate).
  5.1.5 Incubate plates for 24 h at 5% CO_2_, 37°C and 95% humidity (cells should be approximately 80% confluent).
  5.1.6 Replace cell culture media with 100 µL media containing test material or positive control. Desired test sample concentration is determined from HepG2 Hepatocarcinoma Cytotoxicity Assay (NCL Method GTA-2). Treat cells for 24 h.
5.2 Caspase Activation Assay
  5.2.1 Add 100 µL of Apo-ONE® reagent to each well for a final volume of 200 µL/well.
  5.2.2 Cover plate with foil and place on plate shaker (300-500 rpm).
  5.2.3 Incubate for 1 h at room temperature.
  5.2.4 Read fluorescence on plate reader with an excitation of 499 nm and an emission of 521 nm.

Figure 1 Example of HepG2 Cell Culture Appearance

Image was taken with a phase contrast microscope at 225X magnification. Human hepatocarcinoma cells (HepG2) are approximately 80% confluent at this stage.

## 6 Calculations

T o t a l C a s p a s e A c t i v i t y = (( s a m p l e f l u o r e s c e n c e − s a m p l e c e l l f r e e b l a n k f l u o r e s c e n c e ))/(m e a n o f ( m e d i a f l u o r e s c e n c e − m e d i a b l a n k f l o u r e s c e n c e )) * 100

Mean, SD and %CV should be calculated for each positive control and sample.

## 7 Acceptance Criteria

7.1 If a concentration responsive increase or decrease in sample cell-free blank fluorescence is observed, then the nanoparticle is interfering with the assay fluorescence and the non-homogeneous apoptosis assay; NCL Method GTA-6 Hepatocarcinoma Apoptosis Assay should be used instead.
7.2 The fold increase in caspase activity at 24 h for the APAP positive control versus media negative control should be at least 3 (300% of negative control).
7.3 The positive and sample replicate coefficient of variations should be within 50%.
7.4 The assay is acceptable if condition 7.1 and 7.2 are met. Otherwise, the assay should be repeated until acceptance criteria are met.

## 8 References

1 ISO 10993-5 Biological evaluation of medical devices: Part 5 Tests for in vitro cytotoxicity.
2 F1903 – 98 Standard Practice for Testing for Biological Responses to Particles in vitro.
3 Promega Technical Bulletin #295: Apo-ONE® Homogeneous Caspase-3/7 Assay.

## 9 Abbreviations

APAP: acetaminophen
CV: coefficient of variation
FBS: fetal bovine serum
rpm: revolutions per minute
RPMI: Rosewell Park Memorial Institute
SD: standard deviation
Z-DEVD-R110: Rhodamine 110, bis-(N-CBZ-L-aspartyl-L-glutamyl-L-valyl-L-aspartic acid amide

## 10 Appendix

Example of a 96-well plate template.