# NCL Method GTA-6 HepG2 Hepatocarcinoma Apoptosis Assay

Version 1.1

## 1 Introduction

This protocol describes the monitoring of nanoparticle treated human hepatocarcinoma cells (HepG2) for apoptosis, as part of the in vitro NCL preclinical characterization cascade. The protocol utilizes a fluorescent method to determine the degree of caspase-3 activation.

## 2 Principles

Caspase-3 Fluorometric Protease Assay:

Apoptosis in mammalian cells is initiated by activation of the caspase family of cysteine proteases. This assay quantifies caspase-3 activation in vitro by measuring the cleavage of caspase-3 substrate DEVD-7-amino-4-trifluoromethyl coumarin (AFC) to free AFC, which emits yellow-green fluorescence (λ_max_ = 505 nm). This free AFC is measured using a microtiter plate reader (1–3).

## 3 Reagents, Materials, Cell Lines, and Equipment

Note: The NCL does not endorse any of the suppliers listed below; their inclusion is for informational purposes only. Equivalent supplies from alternate vendors can be substituted.

3.1 Reagents
  3.1.1 Acetaminophen (Sigma, A7085)
  3.1.2 RPMI 1640 (Hyclone, SH30096.01)
  3.1.3 Quick Start Bradford Dye Reagent, 1X (Bio-Rad Lab., Inc., Cat. #500-0205)
  3.1.4 Biovision Caspase-3 Fluorometeric Assay Kit (Biovision Cat. # K105-25)
  3.1.5 Nanoparticle
  3.1.6 Fetal Bovine Serum (FBS) (Hyclone, SH30070.03)
  3.1.7 L-glutamine (Hyclone, SH30034.01)
3.2 Materials
  3.2.1 Costar 6 well flat bottom cell culture plates (Costar, 3506)
  3.2.2 Costar 96 well flat bottom cell culture plates (Costar, 3598)
3.3 Cell Lines
  3.3.1 HepG2 (human hepatocarcinoma cells) (ATCC, HB-8065)
3.4 Equipment
  3.4.1 Fluorescent Plate reader (Safire^2^–Tecan or equivalent)
  3.4.2 Microfuge 22R Centrifuge

## 4 Reagent and Control Preparation

4.1 Positive control
  4.1.1 Acetaminophen (APAP) positive control: Add 8 mg to a total volume of 5 mL Maintenance Media (RPMI 1640 with 2 mM L-glutamine and 10% FBS) to make a 10 mM solution. Sterile filter using a 0.2 µm filter.
4.2 Solutions to make up prior (from the Assay kit, Step 3.1.5) (can be stored at 4°C for 6 months)
  4.2.1 Add 10 µL of the DTT solution to 1 mL of the 2X Reaction Buffer.
  4.2.2 Thaw the Cell Lysis buffer and store at 4°C.
  4.2.3 DEVD-AFC is light sensitive, store protected from light.

## 5 Experimental Procedure

5.1 Cell Preparation (or as recommended by supplier)
  5.1.1 Harvest cryopreserved cells from prepared flasks (limit to 20 passages) (Figure 1).
  5.1.2 Count cell concentration using a coulter counter or hemocytometer.
  5.1.3 Dilute cells to a density of 7.5 × 10^5^ cells/mL in RPMI 1640 cell culture media (2 mM L-glutamine, 10% FBS).
  5.1.4 Plate 2 mL of diluted cells to each well of a 6-well plate (1.5 × 10^6^ cells/well). Test samples, positive controls, and media controls are run in triplicate. Timepoints are 0 h (media control), 6 h (sample and media control), 24 h (sample, positive control, and media control), and 48 h (sample and media control) for a total of 24 wells (see Appendix A).
  5.1.5 Incubate plates for 24 h at 5% CO_2_, 37°C and 95% humidity (cells should be approximately 80% confluent).
  5.1.6 Replace cell culture media with 2 mL media containing test material or positive control. Desired test sample concentration is determined from HepG2 Hepatocarcinoma Cytotoxicity Assay (NCL Method GTA-2). Treat cells for designated time period.
5.2 Caspase Activation Assay
  5.2.1 Wash well with 1 mL of room temperature PBS.
  5.2.2 Add 200 µL ice cold lysis buffer to the well, scrape cells and collect in 0.6 mL eppendorf tubes.
  5.2.3 Incubate on ice for 10 minutes and centrifuge at 2000 x g for 5 minutes.
  5.2.4 Transfer 50 µL of supernatant to a 96 well plate reader using the plating format described in Appendix B. Add 50 µL of 2X Reaction Buffer (with DTT) to each sample well. Retain remaining cell lysate for protein determination.
  5.2.5 Add 5 µL of DEVD-AFC substrate (50 µM final concentration) and incubate at 37°C for 1-2 hours.
  5.2.6 Read at fluorescence at ex. 415 nm and em. 505 nm on a microtiter plate reader.
5.3 Protein Determination (Bradford Assay)
  5.3.1 Dilute the 2 mg/mL BSA standard to make a standard curve from 0.125-1.0 mg/mL in 0.5 N NaOH.
  5.3.2 Add 5 µL of standard (from step 5.3.1), cell lysate supernatant (from step 5.2.3), or water blank to each well of a microtiter plate in duplicate according the template in Appendix C.
  5.3.3 Add 250 µL of 1X Dye Reagent to each well of the plate.
  5.3.4 Incubate at room temperature for at least 5 min and not longer than 1 h.
  5.3.5 Read absorbance on a microtiter plate reader at 595 nm.

Figure 1 Example of HepG2 Cell Culture Appearance

Image was taken with a phase contrast microscope at 225X magnification. Human hepatocarcinoma cells (HepG2) are approximately 80% confluent at this stage.

## 6 Calculations

6.1 Protein concentration is determined from the BSA standard curve following linear regression analysis (y = x(slope) + y int). Total protein is determined from the equation:
  T o t a l l y s a t e p r o t e i n ( m g ) = ( (m g p r o t e i n)/(m L) ) * 0.05 m L s a m p l e v o l u m e
6.2 Total Protein Normalized Caspase-3 Activity as a percentage of the control:
  % C o n t r o l A c t i v i t y = ( (s a m p l e f l u o r e s c e n c e)/(t o t a l s a m p l e l y s a t e p r o t e i n) ) / ( (m e a n o f m e d i a c o n t r o l f l u o r e s c e n c e)/(m e a n o f t o t a l m e d i a c o n t r o l l y s a t e p r o t e i n) ) * 100
  Mean, SD and %CV should be calculated for each positive control and sample.

## 7 Acceptance Criteria

7.1 The fold change in caspase activity at 24 hours for the APAP positive control versus media negative control should be at least 3.
7.2 The positive, media control, and sample replicate coefficient of variations should be within 50%.
7.3 The assay is acceptable if condition 7.1 and 7.2 are met. Otherwise, the assay should be repeated until acceptance criteria are met.
7.4 If statistical analysis determines that the total protein normalized control and treated fluorescence are significantly different from one another, then the fold change in fluorescence can be considered meaningful. This result would indicate that sample treatment significantly affected cell apoptosis.

## 8 References

1 ISO 10993-5 Biological evaluation of medical devices: Part 5 Tests for in vitro cytotoxicity.
2 F1903 – 98 Standard Practice for Testing for Biological Responses to Particles in vitro.
3 Wang . (2005) Cell Bio. Int. 29: 489–496.15939633

## 9 Abbreviations

AFC: 7-amino-trifluoromethyl coumarin
APAP: acetaminophen
BSA: bovine serum albumin
CV: coefficient of variation
DEVD: aspartic acid-glutamic acid-valine-aspartic acid
DTT: dithiothreitol
em.: emission
ex.: excitation
FBS: fetal bovine serum
HepG2: human hepatocarcinoma cells
λ_max_: maximal wavelength
PBS: phosphate buffered saline
RPMI: Rosewell Park Memorial Institute
SD: standard deviation

## 10 Appendices

### Appendix A

Example of 6-well plate templates.

All samples are run in triplicate. The following timepoints are recommended: 0 hr (media control), 6 hr (sample and media control), 24 hr (sample, positive control, and media control), and 48 hr (sample and media control) in which case 5 plates will be necessary.

### Appendix B

Example of a 96-well plate template.

Legend: Row (A), Media Negative Control; Row (B), Samples; Row (C), Acetaminophen Positive Control. Each timepoint will be measured individually, as it is harvested.

### Appendix C

Example of a 96-well plate template.

Legend: Pale Yellow, BSA Standards; Green, Media Controls; Blue, Samples; Pink, Positive Controls. Each sample is run in duplicate.