# Appendices

Appendix A: Surgeon General's Conference on Health Disparities and Mental Retardation Summary of the Plenary Session of December 5, 2001: Background Presentations

Appendix B: Participants List

Appendix C: Potential Partners in Realizing the Blueprint

Appendix D: Health Disparities and Mental Retardation: Programs and Creative Strategies to Close the Gap

Appendix E: Summary of the Surgeon General's Listening Session on Health Disparities and Mental Retardation

Appendix F: Surgeon General's Listening Session on Health Disparities and Mental Retardation