# Appendix F: Surgeon General's Listening Session on Health Disparities and Mental Retardation

October 10, 2001

Speakers

Welcome and Opening Comments

Surgeon General David Satcher, M.D., Ph.D., U.S. Department of Health and Human Services

Duane Alexander, M.D., Director, National Institute of Child Health and Human Development, National Institutes of Health (NIH)

Ms. Loretta Claiborne, Self-Advocate

Panel Moderators, NIH Site

Elin Cortijo-Doval, M.Ed.

George Jesien, Ph.D.

Deborah Spitalnik, Ph.D.

Sheryl White-Scott, M.D.

Participating Sites

Civitan International Research Center, University of Alabama at Birmingham

Judy Barclay

Matthew Foster

Alvin Garvin

Wendy Hardy

Elouise Woods

Patsy Wright

Oregon Institute on Disability & Development, Oregon Health & Science University, Portland, Oregon

Judy Cunio

Michael Geheb

Trent Minor

Julie Quaid

Sidney Stuller

Sharon Turner

Judy Wiley

Eunice Kennedy Shriver Center, University of Massachusetts Medical School, Worcester, Massachusetts*

Ana Arango

Sandy Blanes

Billie Chan

David Coulter

Kim Daniels

Yvette Johnson

Ann Ligums

John Morgan

Reginald Raphael

Cindy Smith

Charlotte Spinkston

Bersford Wilson

Waisman Center, University of Wisconsin, Madison, Wisconsin

Cindy Bentley

Barbara Katz

Lynne Schauls

Bill Schwab

Nancy Shook

Jayn Wittenmyer

National Institutes of Health, Bethesda, Maryland

Sally Atwater

Sue Badeau

Renee Bedieux

Robert Bergner

Susan Clark

Jose Cordero

Roxanne Dryden-Edwards

Jackie Golden

Julie Hacker-Yannes

Katrina Johnson

Wanda Jones

Guy Leif

Maureen Mitchell

Liz Oppenheimer

Victor Robinson

Jamie Rutman

Tim Shriver

Irvin Silverman

Ginny Thornburgh

* Due to technical difficulties, the speakers at the Massachusetts site were unable to participate at the time of the actual Listening Session. However, their recorded remarks have been added to the archived videocast of the session and are part of the official record. The entire Listening Session can be viewed at the following site: http://videocast.nih.gov/PastEvents.asp?c=4.