# Appendix C: Potential Partners in Realizing the Blueprint

Conference participants were asked to identify potential partners that may help to diminish the health disparities for people with MR. The names that appear below should not be interpreted in any way as a commitment by a specific agency or organization. Instead, this list is intended to illustrate the potential partnerships on many levels. Furthermore, this list is not exhaustive but includes some of the specific examples that were offered during the Conference.

- Academic Institutions and Organizations
  - Accrediting Bodies
  - - Residency Review Committees
  - American Dental Educators Association
  - Association of American Medical Colleges
  - Association of University Centers on Disabilities
  - Deans of Medical, Dental, Nursing, and other Allied Health Schools
- Civil Rights, Minority Health, and Health Disparities Organizations
  - NAACP
- Employers and Other Purchasers of Health Care
- Families
- Federal and State Regulatory Agencies
  - State Insurance Commissioners
- Federal Government Agencies
  - Department of Education
    - Office of Special Education and Rehabilitative Services
  - Department of Health and Human Services
    - Administration for Children and Families
      - Administration on Developmental Disabilities
    - Agency for Healthcare Research and Quality
    - Centers for Disease Control and Prevention
      - National Center for Birth Defects and Developmental Disabilities
      - National Center for Health Statistics
    - Centers for Medicare & Medicaid Services (formerly HCFA)
    - Health Resources and Services Administration
      - Bureau of Maternal and Child Health
      - Bureau of Primary Health Care
    - Indian Health Service
    - National Institutes of Health
      - National Center on Minority Health and Health Disparities
      - National Institute of Child Health and Human Development
      - National Institute of Dental and Craniofacial Research
      - National Institute of Mental Health
      - National Institute on Aging
      - National Institute on Alcohol Abuse and Alcoholism
    - Office of Minority Health
    - Office of Public Health and Science
      - Office of the Surgeon General
    - Office of the Assistant Secretary for Planning and Evaluation
    - Substance Abuse and Mental Health Services Administration
      - Center for Mental Health Services
  - Department of Labor
  - Social Security Administration
    - Office of Disability
- Federal, State, and Local Government Groups
  - National Association of Counties
  - National Governors Association
  - State Developmental Disabilities Councils
  - State Medicaid Directors
  - State Protection and Advocacy Agencies
- Federal, State, and Local Policymakers
  - State Legislatures
  - U.S. Congress
- National, State, and Local Professional Health and Allied Health Organizations
  - American Academy of Pediatrics
  - American Dental Association
  - American Medical Association
- Pharmaceutical Companies
- Philanthropic Groups and Foundations
  - Joseph P. Kennedy, Jr. Foundation
  - Kaiser Foundation
  - Robert Wood Johnson Foundation
- Public and Private Third-Party Payers
  - Insurance Companies
  - Medicaid
  - Medicare
- Self-Advocate, Parent, and Other Advocacy Groups
  - American Association on Mental Retardation
  - National Committee for Quality Assurance
  - Self Advocates Becoming Empowered
  - Special Olympics, Inc.
  - The Arc of the United States
- State and Local Public Health Departments
- Tribal Community and Health Organizations