# Appendix B: Participants List

SURGEON GENERAL'S CONFERENCE ON HEALTH DISPARITIES AND MENTAL RETARDATION

December 5-6, 2001

Georgetown University Conference Center,Washington, DC

- Deidra Abbott
- Centers for Medicare & Medicaid Services 7500 Security Boulevard, MS S2-14-26 Baltimore, MD 21244-1850 Phone: 410-786-0690 Fax: 410-786-9004 Email: dabbott@cms.hhs.gov

- Diane L. Adams, M.D., M.P.H.
- Director Health Policy, Research and Professional Medical Affairs National Medical Association 1012 Tenth Street, N.W. Washington, DC 20001 Phone: 202-347-1895, 286 Fax: 202-962-0265 Email: dadams@nmanet.org

- Duane Alexander, M.D.
- Director National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A03 9000 Rockville Pike, MSC 2425 Bethesda, MD 20892-2425 Phone: 301-496-3435 Fax: 301-402-1104 Email: da43w@nih.gov

- Rene Anderson
- President Federation of Families P.O. Box 16943 Tampa, FL 33687-6943 Phone: 813-974-2199 Fax: 813-974-7376 Email: randerso@fmhi.usf.edu

- B.J. Arseneau, D.O., M.P.H.
- Chief Psychiatrist Office of Disability Policy and Programs Division of Medical and Vocational Policy Social Security Administration OPNS, MC 3-A-8 Operations 6401 Security Boulevard Baltimore, MD 21235 Phone: 410-966-1970 Email: bernard.arseneau@ssa.gov

- Sally Atwater
- Executive Director President's Committee on Mental Retardation U.S. Department of Health and Human Services Aerospace Building, Room 701 370 L'Enfant Promenade, S.W. Washington, DC 20447 Phone: 202-619-0634 Fax: 202-205-9519 Email: satwater@acf.dhhs.gov

- Susan H. Badeau
- Deputy Executive Director and Public Policy Consultant Joseph P. Kennedy, Jr. Foundation 30 Pelham Road Philadelphia, PA 19119 Phone: 202-824-0316 Fax: 202-824-0351 Email: sbadeau@aol.com

- Eric J. Bailey, Ph.D., M.P.H.
- Medical Anthropologist and Program Director National Center on Minority Health and Health Disparities Office of the Director National Institutes of Health 6707 Democracy Boulevard, Room 800, MSC 5465 Bethesda, MD 20892-5465 Phone: 301-594-1788 Fax: 301-480-4049 Email: baileye@od.nih.gov

- Donna Bernhardt Bainbridge, P.T., Ed.D., ATC
- Director Department of Practice American Physical Therapy Association 1111 North Fairfax Street Alexandria, VA 22314 Phone: 703-706-3170 Fax: 703-838-8910 Email: donnabainbridge@apta.org

- S. Otesia Barr, M.D.
- Medical Director National Children's Center 6200 Second Street, N.W. Washington, DC 20011 Phone: 202-722-2312 Fax: 202-722-2383

- Joan B. Beasley, Ph.D.
- Consultant 184 Bonad Road Chestnut Hill, MA 02467 Phone: 617-469-7391 Fax: 617-469-7391 Email: jbbeasley@rcn.com

- Daniel Bier, M.P.A., M.S.W.
- Associate Director Waisman Center University of Wisconsin at Madison 1500 Highland Avenue, Room S101A Madison, WI 53705-2280 Phone: 608-263-5254 Fax: 608-263-0529 Email: bier@waisman.wisc.edu

- Arnold Birenbaum, Ph.D.
- Associate Director Rose F. Kennedy University Center for Developmental Disabilities Albert Einstein College of Medicine Kennedy Building, Room 204 1410 Pelham Parkway South Bronx, NY 10461 Phone: 718-430-8523 Fax: 718-904-1162 Email: birenbau@aecom.yu.edu

- Aaron Bishop
- Association of University Centers on Disabilities 8630 Fenton Street, Suite 410 Silver Spring, MD 20910 Phone: 301-588-8252 Fax: 301-588-2842 Email: abishop@aucd.org

- Marty Blair
- Staff Writer Association of University Centers on Disabilities 8630 Fenton Street, Suite 410 Silver Spring, MD 20910 Phone: 301-588-8252 Fax: 301-588-2842 Email: mblair@aucd.org

- Betty Bledsoe
- Mentor and Advocate for Special Needs Children The Rainbows 8084 Wallingwood Drive Indianapolis, IN 46256 Phone: 317-842-9079 Fax: 317-841-9093 Email: the-bledsoes@prodigy.net

- Robert Bock, M.A.
- Press Officer Public Information and Communication Branch Office of Science Policy, Analysis and Communication National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-32 9000 Rockville Pike Bethesda, MD 20892 Phone: 301-496-5133 Email: bockr@mail.nih.gov

- David Braddock, Ph.D.
- Associate Vice President for Research and Executive Director Coleman Institute for Cognitive Disabilities University of Colorado System 4001 Discovery Drive, Suite 210, MSC Sys 586 Boulder, CO 80309-0586 Phone: 303-492-0639 Email: braddock@cu.edu

- Kathleen Braden, M.D.
- Director LEND Program National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A18 9000 Rockville Pike, MSC 2425 Bethesda, MD 20892-2425 Phone: 301-496-1877 Fax: 301-496-0588 Email: kathleen.braden@umassmed.edu

- Yvonne E. Bryan, Ph.D., R.N.
- Program Director Office of Extramural Programs National Institute of Nursing Research National Institutes of Health 45 Center Drive, MSC 6300 Bethesda, MD 20892-6300 Phone: 301-594-6908 Fax: 301-480-8260 Email: bryany@mail.nih.gov

- Larry Burt, M.S.
- Program Coordinator Disability and Health Branch National Center on Birth Defects and Developmental Disabilities Centers for Disease Control and Prevention Building 101, Room 2407 4770 Buford Highway, MS F-35 Atlanta, GA 30341 Phone: 770-488-7081 Fax: 770-488-7075 Email: lrb1@cdc.gov

- Nancy N. Cain, M.D.
- Director, Mental Retardation/Developmental Disorders Psychiatric Service Strong Behavior Health Services Department of Psychiatry University of Rochester Medical Center 300 Crittenden Boulevard Rochester, NY 14618 Phone: 585-275-3587 Fax: 585-273-1093 Email: nancy_cain@urmc.rochester.edu

- Faye Calhoun, D.P.A., M.S.
- Associate Director Office of Collaborative Research National Institute on Alcohol Abuse and Alcoholism National Institutes of Health Willco Building, Suite 302 6000 Executive Boulevard Rockville, MD 20852 Phone: 301-443-1269 Fax: 301-480-2358 Email: fcalhoun@mail.nih.gov

- Vincent A. Campbell, Ph.D.
- Health Scientist National Center on Birth Defects and Developmental Disabilities Centers for Disease Control and Prevention 4770 Buford Highway, MS F-35, Building 101 Atlanta, GA 30341 Phone: 770-488-7684 Fax: 770-488-7075 Email: vbc6@cdc.gov

- Paul Casamassimo, D.D.S., M.S.
- Professor and Chair and Chief of Dentistry Section of Pediatric Dentistry Ohio State University College of Dentistry Columbus Children's Hospital 700 Children's Drive Columbus, OH 43205 Phone: 614-722-5651 Fax: 614-722-6791 Email: casamassimo.l@osu.edu

- Jill Center, M.P.H.
- Public Affairs Specialist National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-32 9000 Rockville Pike, MSC 2425 Bethesda, MD 20892-2425 Phone: 301-496-5133 Email: centerj@mail.nih.gov

- Mary C. Cerreto, Ph.D.
- Director of the Center on Self-Determination and Health Department of Family Medicine Boston University Medical School Dowling 5 South Building One Boston Medical Center Place Boston, MA 02118 Phone: 508-653-9165 Fax: 617-414-3345 Email: mcerreto@aol.com

- Mae M. Chin, R.D.H., M.Ed.
- DECOD Clinics Manager Dental Education in Care of Persons with Disabilities Program Department of Oral Medicine University of Washington School of Dentistry Health Sciences Center, Box 356370 1959 Northeast Pacific Street Seattle, WA 98195 Phone: 206-543-4619 Fax: 206-221-5276 Email: mgmchin@u.washington.edu

- Loretta Claiborne
- 1240 Bockius Avenue Abington, PA 19001 Phone: 215-885-3870 Fax: 215-885-9636 Email: ziggygee@aol.com

- Janis Lambert Connallon
- Family Voices-DC Suite 1003 3003 Van Ness Street, N.W. Washington, DC 20008 Phone: 202-537-6046 Email: j-rcon@starpower.net

- Stephen Corbin, D.D.S., M.P.H.
- Dean Special Olympics University Special Olympics, Inc. 1325 G Street, N.W., Suite 500 Washington, DC 20005 Phone: 202-824-0283 Fax: 202-824-0397 Email: scorbin@specialolympics.org

- José F. Cordero, M.D., M.P.H.
- Director National Center on Birth Defects and Developmental Disabilities Centers for Disease Control and Prevention Chamblee - 101, Room 2116 4770 Buford Highway, MS F-34 Atlanta, GA 30341 Phone: 770-488-7150 Fax: 770-488-7156 Email: jfc1@cdc.gov

- Elin Cortijo-Doval, M.Ed.
- Senior Consultant 9600 Kings Croft Drive Glen Allen, VA 23060 Phone: 804-273-1063 Fax: 804-273-0699 Email: elind11@aol.com

- David L. Coulter, M.D.
- Attending Neurologist Department of Neurology Children's Hospital Fegan II 300 Longwood Avenue Boston, MA 02115 Phone: 617-355-2711 Fax: 617-277-1924 Email: coulterdl@aol.com

- M. Doreen Croser
- Executive Director American Association on Mental Retardation 444 North Capitol Street, N.W., Suite 846 Washington, DC 20001-1512 Phone: 202-387-1968 Fax: 202-387-2193 Email: dcroser@aamr.org

- Felix de la Cruz, M.D., M.P.H.
- Acting Branch Chief Mental Retardation and Developmental Disabilities Branch Center for Research for Mothers and Children National Institute of Child Health and Human Development National Institutes of Health Neuroscience Center, Room 4B09 6100 Executive Boulevard, MSC 7510 Bethesda, MD 20892-7510 Phone: 301-496-1383 Fax: 301-496-3791 Email: delacruf@mail.nih.gov

- Kim Daniels
- Parent Consultant to the Vermont Self- Determination Project State of Vermont 103 Main Street Waterbury, VT 05663 Phone: 802-485-8271 Fax: 802-485-4596 Email: kdaniels@together.net

- Sharon Davis, Ph.D.
- Director Professional and Family Services The Arc of the United States 1010 Wayne Avenue, Suite 650 Silver Spring, MD 20910 Phone: 301-565-5478 Fax: 301-565-3843 Email: davis@thearc.org B - 2

- Curtis Decker, J.D.
- Executive Director National Association of Protection and Advocacy Systems 900 Second Street, N.E., Suite 211 Washington, DC 20002 Phone: 202-408-9514 Fax: 202-408-9520 Email: curt@napas.org

- Mark S. Diorio, Ph.D., M.P.H.
- Facility Director Northern Virginia Training Center 9901 Braddock Road Fairfax, VA 22033 Phone: 703-323-4002 Fax: 703-323-4252 Email: mdiorio@nvtc.state.va.us

- Ann Drum, D.D.S., M.P.H.
- Director, Division of Research, Training and Education Maternal and Child Health Bureau Health Resources and Services Administration Parklawn Building, Room 18A-55 5600 Fishers Lane Rockville, MD 20857 Phone: 301-443-0761 Fax: 301-443-4842 Email: adrum@hrsa.gov

- Charles Drum, J.D., Ph.D.
- Director Oregon Institute on Disability and Development Child Development and Rehabilitation Center Oregon Health Sciences University P.O. Box 574 Portland, OR 97207 Phone: 503-494-8047 Fax: 503-494-6868 Email: drumc@ohsu.edu

- Roxanne Dryden-Edwards, M.D.
- Medical Director National Center for Children and Families 6301 Greentree Road Bethesda, MD 20817 Phone: 301-365-4480 Fax: 301-365-2536 Email: redwards@nccf-cares.org

- Susan Dyer
- Research Coordinator Shriver Center University Affiliated Program University of Massachusetts Medical School Eunice Kennedy Shriver Center, Room C116A 200 Trapelo Road Waltham, MA 02452 Phone: 781-642-0261 Fax: 781-642-0162 Email: susan.dyer@umassmed.edu

- Steven M. Eidelman
- Executive Director The Arc of the United States 1010 Wayne Avenue, Suite 650 Silver Spring, MD 20910 Phone: 301-565-5469 Fax: 301-565-3843 Email: eidelman@thearc.org

- Barry Eigen
- Executive Program Policy Officer Office of Disability Office of the Associate Commissioner Social Security Administration Altmeyer Building, Room 560 6401 Security Boulevard Baltimore, MD 21235 Phone: 410-965-2528 Fax: 410-965-6503 Email: barry.eigen@ssa.gov

- Ann L. Elderkin, P.A.
- Senior Health Policy Consultant Office of the Surgeon General Office of the Secretary of Health and Human Services U.S. Department of Health and Human Services Parklawn Building, Room 18-66 5600 Fishers Lane Rockville, MD 20857 Phone: 301-443-0901 Fax: 301-443-1211 Email: aelderkin@osophs.dhhs.gov

- Sanford J. Fenton, D.D.S., M.D.S.
- Chair and ADA Representative Department of Pediatric Dentistry and Community Oral Health University of Tennessee College of Dentistry Dunn Building, Room 5217 875 Union Avenue Memphis, TN 38163 Phone: 901-448-6206 Fax: 901-448-6249 Email: sfenton@utmem.edu

- Michelle Fiorella, D.O.
- Psychiatrist 9004 Harrods Landing Drive Prospect, KY 40059

- Mark Freeman, M.Ed., PA-C
- Director, AAPA Representative Physician Assistant Studies Program Chatham College Woodland Road Pittsburgh, PA 15232 Phone: 412-365-1405 Fax: 412-365-1623 Email: freeman@chatham.edu

- Michael J. Friedlander, Ph.D.
- Chairman Department of Neurobiology University of Alabama at Birmingham Building CIRC, Room 516 1719 Sixth Avenue South, MSC 0021 Birmingham, AL 35294 Phone: 205-934-0100 Fax: 205-975-7394 Email: mjf@nrc.uab.edu

- George Gaines
- Chief, Program and Public Liaison Office National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A03 9000 Rockville Pike, MSC 2425 Bethesda, MD 20892-2425 Phone: 301-435-3447 Fax: 301-402-1104 Email: gainesg@mail.nih.gov

- Isabel Garcia, D.D.S., M.P.H.
- Special Assistant for Science Transfer National Institute of Dental and Craniofacial Research National Institutes of Health Building 45, Room 4AS-19 45 Center Drive Bethesda, MD 20892 Phone: 301-594-7551 Fax: 301-496-9988 Email: isabel.garcia@nih.gov

- Bob Gettings
- Executive Director National Association of State Directors of Developmental Disabilities Services 113 Oronoco Street Alexandria, VA 22314 Phone: 703-683-4202 Fax: 703-684-1395 Email: rgettings@nasddds.org

- Paul Glassman, D.D.S., M.A., M.B.A.
- Associate Dean for Information Technology Director of Advanced Education in General Dentistry Residency Center for Oral Health for People with Special Needs University of the Pacific School of Dentistry 2155 Webster Street San Francisco, CA 94115 Phone: 415-929-6490 Fax: 415-749-3399 Email: pglassman@uop.edu

- Jackie Golden
- Executive Director Inclusion Research Institute 1436 Independence Avenue, S.E. Washington, DC 20003-1536 Phone: 202-546-4464 Fax: 202-546-4465 Email: jlgolden@bellatlantic.net

- Glenn Govin, D.D.S., M.P.H.
- Director, DECOD and Lecturer Department of Oral Medicine University of Washington School of Dentistry Health Sciences Center, Room B316, Box 356370 1959 Northeast Pacific Street Seattle, WA 98195 Phone: 206-543-1546 Fax: 206-685-8412 Email: ggovin@u.washington.edu

- Julie Hacker-Yannes
- 402 Longhorn Crescent Rockville, MD 20850 Phone: 240-683-9453 Email: jyannes@olg.com

- Stanley D. Handmaker, M.D., D.Phil.
- Professor of Pediatrics Department of Pediatrics Health Sciences Center University of New Mexico School of Medicine Ambulatory Care Center 3 West, Room 3221 Albuquerque, NM 87131-5311 Phone: 505-272-0344 Fax: 505-272-6845 Email: shandmaker@salud.unm.edu B - 3

- Wendelyn C. Hardy
- 7420 Newstead Drive Cumming, GA 30041 Phone: 770-667-0250 Email: tinkermau@aol.com

- James C. Harris, M.D.
- Director, Developmental Neuropsychiatry Professor, Psychiatry/Pediatrics Departments of Psychiatry and Pediatrics Johns Hopkins University School of Medicine Johns Hopkins Hospital, Room CMSC 341 600 North Wolfe Street Baltimore, MD 21210 Phone: 410-955-6181 Fax: 410-889-5623 Email: jamesharris@erols.com

- Carmen Held
- Executive Director Denver Aurora Chapter Children's Mental Health 12485 East 13th Avenue Aurora, CO 80011 Phone: 303-507-9863 Fax: 720-859-9367 Email: carheld@msn.com

- Tamar Heller, Ph.D.
- Professor and Interim Head Department of Disability and Human Development College of Applied Health Sciences University of Illinois at Chicago IIDD, Room 436 1640 West Roosevelt Road Chicago, IL 60608-6904 Phone: 312-413-1537 Fax: 312-413-1630 Email: theller@uic.edu

- Camille Hemlock, M.D.
- Associate Medical Director, Mental Retardation/Developmental Disabilities Office of the Medical Director Texas Department of Mental Health and Mental Retardation Central Office, Room 1-107E, MC 655 P.O. Box 12668 Austin, TX 78711-2668 Phone: 512-206-4840 Fax: 512-206-4589 Email: camille.hemlock@mhmr.state.tx.us

- Monica D. Herring
- Parent Advocate 11714 South Laurel Drive, Apt. 20 Laurel, MD 20708 Phone: 240-568-0777 Fax: 301-725-1761 Email: monicadh@msn.com

- Dalice L. Hertzberg, M.S.N., FNP-C, CRRN
- Instructor and Project Coordinator Health Promotion Project JFK Partners, University of Colorado Health Sciences Center Building 401, Room 105 1784 Racine Drive Campus MS F541, P.O. Box 6508 Aurora, CO 80045-0508 Phone: 303-724-0652 Fax: 303-724-0960 Email: dalice.hertzberg@uchsc.edu

- Paula A. Hirt, M.S.
- Director of Programs and Services American Association on Mental Retardation 444 North Capitol Street, N.W., Suite 846 Washington, DC 20001 Phone: 202-387-1968 Fax: 202-387-2193 Email: pahirt@aamr.org

- Deborah Hirtz, M.D.
- Program Director Clinical Trials National Institute of Neurological Disorders and Stroke National Institutes of Health Neuroscience Center 6001 Executive Boulevard, Room 2212, MSC 9525 Bethesda, MD 20892-9525 Phone: 301-496-5821 Fax: 301-480-1080 Email: dh83f@nih.gov

- Henry Hood, D.M.D.
- Director, Dental Services Clinic Hazelwood Center ICF/MR Kentucky Department for Mental Health and Mental Retardation Services 1800 Bluegrass Avenue Box 14506 Louisville, KY 40214-0506 Phone: 502-361-2301, 2366 Fax: 502-366-9779 Email: henry.hood@mail.state.ky.us

- Gail Hunt
- Executive Director National Alliance for Caregiving 4720 Montgomery Lane, Suite 642 Bethesda, MD 20814 Phone: 301-718-8444 Fax: 301-652-7711 Email: gailhunt.nac@erols.com

- Holly Janczak, M.A.
- Director of the Community Living Program Chairperson of the National Association of Qualified Mental Retardation Professionals Trinity Servicers, Inc. 100 Gougar Road Joliet, IL 60432 Phone: 815-485-4781 Fax: 815-485-9145 Email: trinityhj@aol.com

- Matthew P. Janicki, Ph.D.
- Director for Technical Assistance Rehabilitation Research and Training Center on Aging with Developmental Disabilities University of Illinois at Chicago University at Albany Richardson Hall 280 Albany, NY 12222 Phone: 518-442-3791 Fax: 518-877-3357 Email: janickimp@aol.com

- Jane Jasek, R.D.H., M.P.A.
- Manager Access and Community Health American Dental Association 211 East Chicago Avenue Chicago, IL 60611 Phone: 312-440-2868 Fax: 312-440-4640

- George Jesien, Ph.D.
- Executive Director Association of University Centers on Disabilities 8630 Fenton Street, Suite 410 Silver Spring, MD 20910 Phone: 301-588-8252 Fax: 301-588-2842 Email: gjesien@aucd.org

- Robert S. Johns
- Executive Director National Dental Association 3517 16th Street, N.W. Washington, DC 20010 Phone: 202-588-1697 Fax: 202-588-1244 Email: rsjohns@ndaonline.org

- Tracy B. Johnson
- Southwest Center 860 West 50 South Tropic, UT 84776 Phone: 435-679-8824 Fax: 435-679-8905 Email: moetracy@color-country.net

- Lisa Kaeser, J.D.
- Senior Program Analyst Office of Program and Public Liaison National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-03 9000 Rockville Pike Bethesda, MD 20892-2425 Phone: 301-496-0536 Fax: 301-402-1104 Email: kaeserl@mail.nih.gov

- Theodore A. Kastner, M.D., M.S.
- President Developmental Disabilities Health Alliance, Inc. 1285 Broad Street Bloomfield, NJ 07003 Phone: 973-338-4200 Fax: 973-338-4440 Email: tkastner@ddha.com

- Cille Kennedy, Ph.D.
- Operations Research Analyst Office of Disability, Aging and Long-Term Care Policy Office of the Assistant Secretary for Planning and Evaluation U.S. Department of Health and Human Services Hubert H. Humphrey Building, Room 424E 200 Independence Avenue, S.W. Washington, DC 20201 Phone: 202-690-6443 Fax: 202-401-7733 Email: ckennedy@osaspe.dhhs.gov

- Bonnie Kerker, M.P.H.
- Department of Epidemiology and Public Health Yale University 60 College Street, Room 310 New Haven, CT 06520 Phone: 203-785-2862 Fax: 203-785-6287 Email: bonnie.kerker@yale.edu B - 4

- Woodie Kessel, M.D., M.P.H.
- Assistant Surgeon General Office of Public Health and Science Office of the Secretary of Health and Human Services U.S. Department of Health and Human Services Hubert H. Humphrey Building, Room 728G 200 Independence Avenue, S.W. Washington, DC 20201 Phone: 202-401-0749 Fax: 202-205-9478 Email: wkessel@hrsa.gov

- Timothy J. Kowalski, D.O.
- President American College of Osteopathic Neurologists and Psychiatrists South Carolina Department of Mental Health American Osteopathic Association WSHPI, Cottage C 1800 Colonial Drive Columbia, SC 29202 Phone: 803-898-2270 Fax: 803-898-1596 Email: tjk53@wshpi.dmh.state.sc.us

- Gloria Krahn, Ph.D.
- Oregon Institute on Disability and Development Oregon Health Sciences University 707 Southwest Gaines Road P.O. Box 574 Portland, OR 97207-0574 Phone: 503-494-8364 Email: krahng@ohsu.edu

- Fred J. Krause, M.S.
- Vice President American Association on Health and Disability 368 Heritage Drive Gettysburg, PA 17325 Phone: 717-337-0465 Fax: 717-338-0612 Email: krause@desupernet.net

- K. Charlie Lakin, Ph.D.
- University of Minnesota 150 Pillsbury Drive, S.E. Minneapolis, MN 55455 Phone: 612-624-5005 Fax: 612-625-6619 Email: lakin001@umn.edu

- Alan S. Levine
- Senior Program Specialist Office of Evaluation and Inspections Office of the Inspector General U.S. Department of Health and Human Services Wilbur J. Cohen Building, Room 5650 330 Independence Avenue, S.W. Washington, DC 20201 Phone: 202-619-3409 Fax: 202-401-0556 Email: alevine@os.dhhs.gov

- Joel M. Levy, D.S.W.
- Chief Executive Officer Administrative Offices YAI/National Institute for People With Disabilities 460 West 34th Street, 11th Floor New York, NY 10001 Phone: 212-273-6110 Fax: 212-947-7524 Email: jmlcares@yai.org

- Ronald L. Lindsay, M.D., FAAP
- Medical Director Nisonger Center Ohio State University McCampbell Hall, Room 357C 1581 Dodd Drive Columbus, OH 43210-1257 Phone: 614-292-6816 Fax: 614-292-3727 Email: lindsay.34@osu.edu

- Michelle Link
- Office Manager School Products and Equipment Co. 1711 North Griffin Street Bismarck, ND 58501 Phone: 701-223-5470 Fax: 701-222-0207 Email: mmlink@mcleodusa.net rmlink@home.com

- Julian A. Manelli, M.A.
- Special Assistant Office of Disability Social Security Administration Altmeyer Building, Room 545 6401 Security Boulevard Baltimore, MD 21235 Phone: 410-965-9022 Fax: 410-965-6503 Email: julian.a.manelli@ssa.gov

- Lee Marrone, M.A., M.S.
- School-Camp Director Lee Mar School and Camp 360 East 72nd Street, Suite A711 New York, NY 10021 Phone: 212-988-7260 Fax: 212-988-7261 Email: gtour400@aol.com

- Philip B. May, Jr., M.D.
- Director, Developmental Medicine Program Department of Medicine Robert Wood Johnson Medical School Hunterdon Developmental Center P.O. Box 4003 Clinton, NJ 08809-4003 Phone: 908-735-4031, 1072 Fax: 908-730-1322 Email: pmay1@mindspring.com

- Cate McClain, M.D., P.T.
- Director Center for Development and Disability Department of Pediatrics University of New Mexico School of Medicine 2300 Menaul Boulevard, N.E. Albuquerque, NM 87107 Phone: 505-272-6233 Fax: 505-272-5280 Email: cmcclain@unm.edu

- Susan S. McDermott, M.D.
- Neurology Public Policy Fellow National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-11 9000 Rockville Pike, MSC 2425 Bethesda, MD 20892-2425 Phone: 301-435-3427 Fax: 301-496-0588 Email: mcdermos@mail.nih.gov

- Suzanne McDermott, Ph.D.
- Associate Professor Department of Family and Preventive Medicine University of South Carolina School of Medicine 6 Richland Medical Park Columbia, SC 29203 Phone: 803-434-2445 Fax: 803-434-7529 Email: suzanne.mcdermott@palmettohealth.org

- John McGrath, Ph.D.
- Branch Chief Public Information and Communications Branch Office of Science Policy, Analysis and Communication National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-18 9000 Rockville Pike, MSC 2425 Bethesda, MD 20892 Phone: 301-496-5133 Email: mcgrathj@mail.nih.gov

- William J. McIlvane, Ph.D.
- Director Shriver Mental Retardation and Developmental Disabilities Center University of Massachusetts Medical School 200 Trapelo Road Waltham, MA 02452 Phone: 781-642-0153 Fax: 781-642-0196 Email: william.mcilvane@umassmed.edu

- Terrence McNelis, M.P.A.
- Board Member, National Association for the Dually Diagnosed Northwestern Human Services 11082 Knights Road Philadelphia, PA 19154 Phone: 215-632-9040, 131 Fax: 215-827-4011 Email: tmcnelis@nhsonline.org

- Merle McPherson, M.D., M.P.H.
- Director Division of Services for Children with Special Health Needs Maternal and Child Health Bureau Health Resources and Services Administration Parklawn Building, Room 18A-27 5600 Fishers Lane Rockville, MD 20857 Phone: 301-443-4948 Fax: 301-443-1728 Email: mmcpherson@hrsa.gov

- Edgardo J. Menvielle, M.D.
- IPA Child and Adolescent Treatment and Preventive Intervention Research Branch Division of Services and Intervention Research National Institute of Mental Health National Institutes of Health Neuroscience Center, Room 7149 6001 Executive Boulevard, MSC 9633 Bethesda, MD 20892-9633 Phone: 301-443-4283 Fax: 301-443-4045 Email: emenviel@mail.nih.gov B - 5 B - 6

- Christine E. Miller, R.D.H., M.H.S., M.A.
- Associate Professor and Director President, Academy of Dentistry for People with Disabilities Center of Oral Health for People with Special Needs Dental Practice Department University of the Pacific School of Dentistry 2155 Webster Street, Suite 500 San Francisco, CA 94115 Phone: 415-929-6426 Fax: 415-749-3399 Email: cmiller@uop.edu

- Maureen Mitchell
- Congressional Fellow, Senator Olympia Snowe's Office Joseph P. Kennedy, Jr. Foundation Russell Senate Office Building, Room 154 Washington, DC 20510 Phone: 202-224-8673 Fax: 202-228-1071 Email: maureen_mitchell@snowe.senate.gov

- John Morgan, D.D.S.
- Dentist in Chief and Administrative Director Tufts Dental Facilities Tufts University School of Dental Medicine 200 Trapelo Road Waltham, MA 02452 Phone: 781-899-6020 Fax: 781-893-1829 Email: john.morgan@tufts.edu

- Kenneth P. Moritsugu, M.D., M.P.H.
- Deputy Surgeon General Rear Admiral Office of the Secretary U.S. Department of Health and Human Services Parklawn Building 5600 Fishers Lane Rockville, MD 20857 Phone: 301-443-4000 Fax: 301-443-8590 Email: kmoritsugu@osophs.dhhs.gov

- Jill Morrow, M.D.
- Medical Director Office of Mental Retardation Department of Public Welfare Commonwealth of Pennsylvania Health and Welfare Building, Room 423 Seventh and Forster Streets Harrisburg, PA 17105 Phone: 717-705-2638 Fax: 717-783-5662 Email: jmorrowgor@state.pa.us

- Eve K. Moscicki, Sc.D., M.P.H.
- Senior Advisor Office of the Surgeon General Office of the Secretary of Health and Human Services U.S. Department of Health and Human Services 5600 Fishers Lane, Room 18-67 Rockville, MD 20857 Phone: 301-443-1773 Fax: 301-443-3574 Email: em15y@nih.gov

- Wendy M. Nehring, Ph.D., R.N., FAAN
- Professor and Director of Undergraduate Programs School of Nursing Southern Illinois University at Edwardsville Alumni Hall, Room 2120, MC 1066 Edwardsville, IL 62026-1066 Phone: 618-650-3934 Fax: 618-650-3854 Email: wnehrin@siue.edu

- Liz Obermayer
- The Council on Quality and Leadership 100 West Road, Suite 406 Towson, MD 21204 Phone: 410-583-0060 (work) 410-583-9090 (home) Email: lizobe@aol.com

- David O'Hara, Ph.D.
- Associate Director Westchester Institute for Human Development Cedarwood Hall Valhalla, NY 10595 Phone: 914-493-8202 Email: david_ohara@nymc.edu

- Serene Olin, Ph.D.
- Office of the Director National Institute of Mental Health National Institutes of Health Neuroscience Center, Room 8207 6001 Executive Boulevard Bethesda, MD 20892 Phone: 301-443-7856 Email: solin@mail.nih.gov

- Mary Lou Oster-Granite, Ph.D.
- Health Scientist Administrator Mental Retardation and Developmental Disabilities Branch Center for Research for Mothers and Children National Institute of Child Health and Human Development National Institutes of Health 6100 Executive Boulevard, Room 4B09D, MSC 7510 Bethesda, MD 20892-7510 Phone: 301-435-6866 Fax: 301-496-3791 Email: mo96o@nih.gov

- Pamela Owens, Ph.D.
- Staff Service Fellow Center for Organization and Delivery Studies Agency for Healthcare Research and Quality EOC Building, Room 6W42 2101 East Jefferson Street, Suite 605 Rockville, MD 20852 Phone: 301-594-0759 Fax: 301-594-2314 Email: powens@ahrq.gov

- Sharon A. Oxx, R.N., CDDN
- Director of Health Services Office of Quality Assurance Department of Mental Retardation State of Massachusetts 160 North Washington Street Boston, MA 02114 Phone: 617-624-7792 Fax: 617-624-7577 Email: sharon.oxx@dmr.state.ma.us

- Delores Parron, Ph.D.
- Scientific Advisor Office of the Director National Institutes of Health Building 1, Room 326 9000 Rockville Pike Bethesda, MD 20892 Phone: 301-451-9677 Email: parrond@od.nih.gov

- Robert Pasternack, Ph.D.
- Assistant Secretary Office of Special Education and Rehabilitative Services U.S. Department of Education 330 C Street, S.W., Room 3006 Washington, DC 20202 Phone: 202-205-5965 Fax: 202-205-9252 Email: robert.pasternack@ed.gov

- Steven P. Perlman, D.D.S., M.Sc.D.
- Global Clinical Director, Special Olympics Special Smiles Special Olympics, Boston University 77 Broad Street Lynn, MA 01902 Phone: 781-599-2900 Fax: 781-598-1670 Email: sperlman@bu.edu

- Loretta Petty
- Deputy Assistant Secretary Office of Special Education and Rehabilitative Services U.S. Department of Education 330 C Street, S.W., Room 3006 Washington, DC 20202-1500 Phone: 202-205-5465 Fax: 301-205-9252

- Debbie Powell
- Special Assistant to the Commissioner Administration on Developmental Disabilities Administration for Children and Families U.S. Department of Health and Human Services Hubert H. Humphrey Building, Room 300F Aerospace Building, 370 L'Enfant Promenade Washington, DC 20447 Phone: 202-690-5911 Fax: 202-690-6904 Email: dpowell@acf.dhhs.gov

- Rick Rader, M.D.
- Director M.J. Kent Habilitation Center Orange Grove Center 615 Derby Street Chattanooga, TN 37404 Phone: 423-493-2936 Fax: 423-493-2926 Email: babctrmd@aol.com

- Roseann Rafferty
- National Institute for Disability and Rehabilitative Research Office of Special Education and Rehabilitative Services U.S. Department of Education 330 C Street, S.W., Room 3428 Washington, DC 20202 Phone: 202-205-5867 Fax: 202-205-9252

- Sharon Landesman Ramey, Ph.D.
- Director and Professor Civitan International Research Center University of Alabama at Birmingham 1719 Sixth Avenue South, CIRC 137 Birmingham, AL 35294-0021 Phone: 205-934-8542 Fax: 205-975-6330 Email: sramey@uab.edu B - 7

- Clyde E. Rapp, Jr., M.D.
- Director Center for Adults with Development Disabilities Albert Einstein Medical Center Levy 2 Building 5501 Old York Road Philadelphia, PA 19072 Phone: 215-456-6191 Fax: 215-456-2356

- Elena V. Rios, M.D., M.S.P.H.
- President National Hispanic Medical Association 1411 K Street, N.W., Suite 200 Washington, DC 20005 Phone: 202-628-5895 Fax: 202-628-5898 Email: nhma@nhmamd.org

- Deidra Roach, M.D.
- Medical Officer Office of Collaborative Research National Institute on Alcohol Abuse and Alcoholism National Institutes of Health Willco Building, Suite 302 6000 Executive Boulevard Rockville, MD 20852 Phone: 301-443-5820 Fax: 301-480-2358 Email: droach@mail.nih.gov

- Beverly Roberts, M.Ed.
- Director, Mainstreaming Medical Care The Arc of New Jersey 985 Livingston Avenue North Brunswick, NJ 08902 Phone: 732-246-2525, 34 Fax: 732-214-1834 Email: broberts@arcnj.org

- Lahoma Roebuck, M.S.W.
- Public Health Advisor/Eldercare and Disabilities Division of Clinical and Preventive Services Indian Health Service 12300 Twinbrook Parkway, Suite 605 Rockville, MD 20852 Phone: 301-443-1068 Fax: 301-443-7623 Email: lroebuck@hqe.ihs.gov

- Mona Rowe, M.C.D.
- Deputy Director Office of Science Policy, Analysis and Communication National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-18 9000 Rockville Pike, MSC 2425 Bethesda, MD 20892-2425 Phone: 301-496-1877 Fax: 301-496-0588 Email: rowem@exchange.nih.gov

- Edgar Bear Running, I
- Emergency Manager Emergency Management Division Oglala Sioux Tribe Box H Pine Ridge, SD 57770 Phone: 605-867-6074, 221 Fax: 605-867-6076 Email: ostwwt@gwtc.net

- David Satcher, M.D., Ph.D.
- U.S. Surgeon General Office of the Secretary U.S. Department of Health and Human Services Parklawn Building 5600 Fishers Lane, Room 18-66 Rockville, MD 20857 Phone: 301-443-4000 Fax: 301-443-8590 Email: dsatcher@osophs.dhhs.gov

- Lynne M. Schauls
- 2702 150th Street Luck, WI 54853 Phone: 715-472-2002 Email: garlyn@lakeland.ws

- Ron Schoenfeld, Ph.D.
- Office of the Surgeon General Office of the Secretary U.S. Department of Health and Human Services Parklawn Building, Room 18-66 5600 Fishers Lane Rockville, MD 20857 Phone: 301-443-2132 Fax: 301-443-3574 Email: rschoenfeld@osophs.dhhs.gov

- Mary Jean Schumann, M.S.N., M.B.A, CPNP
- Director of Nursing Practice and Policy American Nurses Association 600 Maryland Avenue, S.W., Suite 100W Washington, DC 20024 Phone: 202-651-7043 Fax: 202-651-7349 Email: mschum@ana.org

- Quandra Scudder
- Program Analyst Neurogenetics Cluster National Institute of Neurological Disorders and Stroke National Institutes of Health Neuroscience Center 6001 Executive Boulevard, Room 2145 Bethesda, MD 20892 Phone: 301-496-5745 Fax: 301-402-1501 Email: qs3y@nih.gov

- Tom Seekins, Ph.D.
- Director Rural Institute on Disabilities University of Montana 52 Corbin Hall Missoula, MT 59812-7056 Phone: 406-243-2654 Fax: 406-243-2349 Email: ruraldoc@selway.umt.edu

- Marsha M. Seltzer, Ph.D.
- Acting Director Waisman Center University of Wisconsin at Madison 1500 Highland Avenue, Room T201 Madison, WI 53705-2280 Phone: 608-263-5940 Fax: 608-263-3300 Email: mseltzer@waisman.wisc.edu

- Jonathan D. Shenkin, D.D.S., M.P.H.
- Resident Department of Pediatric Dentistry University of Iowa College of Dentistry 201 Dental Science South Iowa City, IA 52242-1001 Phone: 319-335-7488 Fax: 319-335-5508 Email: jonathan-shenkin@uiowa.edu

- Patricia Sheridan
- Manager National Oral Health Information Clearinghouse National Institute of Dental and Craniofacial Research National Institutes of Health Building 45, Room 4AS-19, MC 6400 45 Center Drive Bethesda, MD 20892-6400 Phone: 301-594-7557 Fax: 301-496-9988 Email: patricia.sheridan@nih.gov

- Diane S. Shinberg, Ph.D.
- Health Analyst National Center for Health Statistics Centers for Disease Control and Prevention 875 Presidential Building, MS P-08 6525 Belcrest Road Hyattsville, MD 20782 Phone: 301-458-4669 Fax: 301-458-4035 Email: dshinberg@cdc.gov

- Eunice Kennedy Shriver
- Executive Vice President Joseph P. Kennedy, Jr. Foundation 1325 G Street, N.W., Suite 500 Washington, DC 20005 Phone: 202-393-1250 Email: emobley@specialolympics.org

- Sargent Shriver
- Chairman of the Board Special Olympics, Inc. 1325 G Street, N.W., Suite 500 Washington, DC 20005-3104 Phone: 202-824-0242 Fax: 202-628-0067

- Timothy Shriver, Ph.D.
- President and Chief Executive Officer Special Olympics, Inc. 1325 G Street, N.W., Suite 500 Washington, DC 20005-3104 Phone: 202-824-0242 Fax: 202-628-0067 Email: tshriver@specialolympics.org

- Elliott W. Simon, Ph.D.
- Executive Director, Clinical Services Elwyn, Inc. Administration Building, Room 230 111 Elwyn Road Elwyn, PA 19063 Phone: 610-891-2422 Fax: 610-891-2662

- Thomas Spangler, J.D., M.L.I.R.
- Director Legislative and Regulatory Policy American Dental Association 1111 14th Street, N.W., Suite 1100 Washington, DC 20005 Phone: 202-789-5179 Fax: 202-789-2258 Email: spanglert@ada.org

- Giovanna Spinella, M.D.
- Director, Neurogenetics Program Neurogenetics Cluster Division of Extramural Research National Institute of Neurological Disorders and Stroke National Institutes of Health Neuroscience Center 6001 Executive Boulevard, Room 2136, MSC 9525 Bethesda, MD 20892-9525 Phone: 301-496-5745 Fax: 301-402-1501 Email: gs41b@nih.gov

- Deborah M. Spitalnik, Ph.D.
- Executive Director Elizabeth M. Boggs Center on Developmental Disabilities Department of Pediatrics Robert Wood Johnson Medical School University of Medicine and Dentistry of New Jersey Liberty Plaza, Room 3500 335 George Street New Brunswick, NJ 08901 Phone: 732-235-9326 Fax: 732-235-9330 Email: spitalde@umdnj.edu

- Laurence R. Stanford, Ph.D.
- Health Science Administrator Mental Retardation and Developmental Disabilities Branch Center for Research for Mothers and Children National Institute of Child Health and Human Development National Institutes of Health 6100 Executive Boulevard, Room 4B09F, MSC 7510 Bethesda, MD 20892-7510 Phone: 301-496-1385 Fax: 301-496-3791 Email: lstanfor@mail.nih.gov

- Christine Stile, MAPW, E.L.S.
- Writer/Editor National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-32 9000 Rockville Pike, MSC 2425 Bethesda, MD 20892-2425 Phone: 301-496-5133 Email: stilec@mail.nih.gov

- Susanne Strickland
- Program Analyst National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-18 9000 Rockville Pike, MSC 2425 Bethesda, MD 20892-2425 Phone: 301-496-1877 Email: strickls@mail.nih.gov

- Sue Swenson
- Executive Director Joseph P. Kennedy, Jr. Foundation 1325 G Street, N.W., Suite 500 Washington, DC 20005 Phone: 202-393-1250 Email: sswenson@specialolympics.org

- Damon Thompson
- Public Affairs Director Office of Public Health and Science Office of the Secretary U.S. Department of Health and Human Services Hubert H. Humphrey Building, Room 725H 200 Independence Avenue, S.W. Washington, DC 20201 Phone: 202-205-1842 Email: dthompson@osophs.dhhs.gov

- Teri Toothman
- Executive Director Mountain State Parents, Children, and Adolescents Network 20 Richmond Avenue Wheeling, WV 26003 Phone: 304-233-5399 Fax: 304-233-3847 Email: ttoothman@mspcan.org

- Sharon P. Turner, D.D.S., J.D.
- Dean School of Dentistry Oregon Health Sciences University 611 Southwest Campus Drive, Room 610, MC SD610 Portland, OR 97201-3097 Phone: 503-494-8801 Fax: 503-494-8351 Email: turnersp@ohsu.edu

- Joseph M. Valenzano, Jr., M.B.A.
- President, Chief Executive Officer, and Publisher Exceptional Parent Magazine 65 Route 4 East Riveredge, NJ 07661 Phone: 201-489-0562 Fax: 201-489-0074 Email: jvalenzano@eparent.com

- Peter C. van Dyck, M.D., M.P.H.
- Director Office of the Associate Administrator Maternal and Child Health Bureau Health Resources and Services Administration Parklawn Building, Room 18-05 5600 Fishers Lane Rockville, MD 20857 Phone: 301-443-2170 Fax: 301-443-1797 Email: pvandyck@hrsa.gov

- Benedetto Vitiello, M.D.
- Branch Chief Child and Adolescent Treatment and Preventive Intervention Research Branch Division of Services and Intervention Research National Institute of Mental Health National Institutes of Health Neuroscience Center, Room 7149 6001 Executive Boulevard, MSC 9633 Bethesda, MD 20892-9633 Phone: 301-443-4283 Fax: 301-443-4045 Email: bvitiell@mail.nih.gov

- Ann Wagner, Ph.D.
- Chief, Autism and Pervasive Development Disorders Intervention Research Program Child and Adolescent Treatment and Preventive Intervention Research Branch Division of Services and Intervention Research National Institute of Mental Health National Institutes of Health Neuroscience Center, Room 7149 6001 Executive Boulevard Bethesda, MD 20892-9633 Phone: 301-443-3633 Fax: 301-443-4045 Email: awagner@mail.nih.gov

- Mark L. Wagner, D.M.D.
- Director, Health and Research Initiatives Program Development and Learning Special Olympics University Special Olympics, Inc. 1325 G Street, N.W., Suite 500 Washington, DC 20005-3104 Phone: 202-715-1148 Fax: 202-824-0397 Email: mwagner@specialolympics.org

- Keri-Lyn Wall, M.S.W.
- Public Information and Communications Branch Office of Science Policy, Analysis and Communication Office of the Director National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-32 9000 Rockville Pike Bethesda, MD 20892 Phone: 301-594-8029 Email: wallk@mail.nih.gov

- Elizabeth Wehr, J.D.
- Office of Science Policy, Analysis and Communication Office of the Director National Institute of Child Health and Human Development National Institutes of Health Building 31, Room 2A-11 9000 Rockville Pike Bethesda, MD 20892 Phone: 301-496-1877 Fax: 301-496-0588 Email: wehre@mail.nih.gov

- Sheryl White-Scott, M.D.
- Director St. Charles Developmental Disabilities Program St. Vincents Catholic Medical Centers of New Jersey St. Joseph's Hospital 79-11 Parsons Boulevard Flushing, NY 11366 Phone: 718-558-6210 Fax: 718-558-6315 Email: swhite@cmcny.com