# MENTAL HEALTH AND SUBSTANCE USE DISORDERS: IMPAIRMENT IN FUNCTIONING

Mental health and substance use disorders are among the leading causes of disability in the United States (World Health Organization, 2004). Twenty-five percent of all years of life lost to disability and premature mortality are a result of mental illness (Centers for Disease Control and Prevention, 2010).

The symptoms of behavioral health disorders may affect a person's ability to function each day. People with these disorders may find it difficult to maintain interpersonal relationships, find and sustain employment, complete work or school assignments, or care for themselves or their families.

This section describes impairment or difficulty in functioning related to mental health and substance use disorders among adults, adolescents, and children. Co-occurring disorders—simultaneously occurring mental health and substance use disorders—and their effects on impairment in daily functioning among adults are also addressed.

## 3.1 Adults

### 3.1.1 Serious Mental Illness and Levels of Impairment in Functioning

The term “serious mental illness” has long been used to differentiate between persistent mental health disorders that are disabling or impairing and disorders that result in less severe levels of distress and impairment. Disorders such as schizophrenia and bipolar disorder are typically considered serious mental illnesses because of the nature and extent of their symptoms. For example, the hallucinations or delusions from schizophrenia interfere with daily functioning. However, other disorders, such as major depressive disorder, may have symptoms that are severe and others that are not severe. These disorders would be categorized as serious mental illness only when symptoms severely hinder functioning and persist.

Data about the prevalence of mental illness and related impairment are available from a variety of surveys. These surveys typically measure mental illness and impairment in different ways. The National Survey on Drug Use and Health (NSDUH), for example, asks respondents about symptoms of psychological distress in the past year and about difficulty in conducting daily activities as a result of “emotions, nerves, or mental health.” Responses are used to classify people as having no mental illness or having mental illness with mild, moderate, or serious impairment.

Other national surveys that are frequently used to measure mental illness and impairment in functioning are the National Health Interview Survey (NHIS), the National Comorbidity Survey Replication (NCS-R) and its adolescent counterpart (NCS-A), the National Epidemiologic Survey on Alcohol and Related Conditions (NESARC), and the National Health and Nutrition Examination Survey (NHANES). For more information about how mental health or impairment is measured in these surveys, see Appendix B (Data Source Descriptions).

In 2005, Kessler and colleagues reported that approximately 26 percent of adults were estimated to have at least one mental health or substance use disorder in the past year. Approximately 6 percent of adults were categorized as having serious mental illness, meaning that someone reported either a serious suicide attempt or a mental health or substance use disorder with severe impairment in the past year. Findings from the 2010 and 2011 NSDUHs indicate that an estimated 18 percent of adults had mental illness in the past year with some level of impairment (Figure 3-1).

Figure 3-1 No past year mental illness and past year mental illness with impairment among adults: 2010–2011 combined

SOURCE: National Survey on Drug Use and Health, 2010 (revised March 2012) and 2011 (revised May 2013), Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. See Appendix Table A-5 for detailed source information.

Figure 3-1 is a bar chart showing no past year mental illness and mental illness with mild, moderate, and serious impairment among adults for 2010 and 2011 combined. Among adults, 82.1% had no mental illness, 9.6% had mental illness with mild impairment, 4.4% had mental illness with moderate impairment, and 4.0% had mental illness with serious impairment.

Impairment also can be measured by assessing various areas of daily functioning. Compared to people without mental illness, people with serious mental illness are more likely to be unemployed, to be arrested, and to change residences (Figure 3-2). Figure 3-2 shows that adults experiencing mental illness with serious impairment were more than twice as likely as those experiencing no mental illness to report fair or poor health and nearly twice as likely to have visited a hospital emergency room in the past year. Likewise, people with mental illness are more likely to have physical health problems (Scott et al., 2009).

Figure 3-2 Unemployment, past year arrest, current health, past year emergency room visits, and residential instability among adults, by past year mental health status: 2010–2011 combined

SOURCE: National Survey on Drug Use and Health, 2010 (revised March 2012) and 2011 (revised May 2013), Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. See Appendix Table A-6 for detailed source information.

Figure 3-2 is a bar chart showing unemployment, past year arrest, current health, past year emergency room visits, and residential instability among adults by past year mental health status for 2010 and 2011 combined. Current unemployment was 5.8% among adults with no mental illness, 7.2% among adults with mental illness with mild impairment, 8.5% among adults with mental illness with moderate impairment, and 9.1% among adults with mental illness with serious impairment. Past year arrest was 2.2% among adults with no mental illness, 3.2% among adults with mental illness with mild impairment, 4.8% among adults with mental illness with moderate impairment, and 7.7% among adults with mental illness with mental illness with serious impairment. Fair or poor current health was 10.7% among adults with no mental illness, 22.1% among adults with mental illness with mild impairment, 25.6% among adults with mental illness with moderate impairment, and 34.4% among adults with mental illness with serious impairment. Past year emergency room visits was 25.7% among adults with no mental illness, 37.5% among adults with mental illness with mild impairment, 39.4% among adults with mental illness with moderate impairment, and 47.3% among adults with mental illness with serious impairment. Residential instability was 5.7% among adults with no mental illness, 9.6% among adults with mental illness with mild impairment, 10.5% among adults with mental illness with moderate impairment, and 14.7% among adults with mental illness with serious impairment.

Research shows that serious mental illness is associated with lower socioeconomic status (Costello, Compton, Keeler, & Angold, 2003) and inadequate housing (Tsai, Stroup, & Rosenheck, 2011). Also, people with serious mental illness are more likely than others in the general population to be perpetrators and victims of violence (Goodman et al., 2001; Hiday, Swanson, Swartz, Borum, & Wagner, 2001). A review of the literature on violence perpetration and violent victimization of people with serious mental illness by Choe, Teplin, and Abram (2008) indicates that rates of violent victimization are higher than rates of violence perpetration among people with serious mental illness. The authors concluded that violent victimization is a greater public health concern than perpetration.

### 3.1.2 Co-Occurring Mental Health and Substance Use Disorders

Mental health and substance use disorders are not independent of one another. People with a mental health disorder are at increased risk of developing a substance use disorder and vice versa. About half (51 percent) of NCS-R respondents who had a mental health disorder at some time in their lifetime also had a substance use disorder in their lifetime and vice versa (Kessler, 2004). In 2004, Grant and colleagues reported findings from NESARC that indicate significantly higher rates of past year major depressive episode (MDE) among adults with a past year substance use disorder (15 percent) than among those without a past year substance use disorder (6 percent). Similar results are reported from the 2010 NSDUH. Among adults who had an MDE in 2010, 22 percent were dependent on or abused alcohol or illicit drugs in the past year, compared with 8 percent among adults who had not experienced a past year MDE (SAMHSA, 2012).

Co-occurring mental health and substance use disorders can be quite complex to address. People with co-occurring disorders are more difficult to treat, more likely to have treatment adherence problems, and more likely to have poorer outcomes than those with only a mental health or substance use disorder (Herbeck, Fitek, Svikis, Montoya, Marcus, & West, 2005; Kelly, Daley, & Douaihy, 2012).

### 3.1.3 Co-Occurring Disorders and Levels of Impairment in Functioning

The functional impairment associated with co-occurring mental health and substance use disorders is often more pronounced than impairment associated with either a mental health disorder or a substance use disorder alone. Figure 3-3 shows rates of current unemployment, past year arrest, current health, past year emergency room visits, and residential instability among adults by their past year mental health and substance use status.

Figure 3-3 Unemployment, past year arrest, current health, past year emergency room visits, and residential instability among adults, by past year mental health and substance use disorder status: 2010–2011 combined

^1^ Substance use disorder includes disorders for alcohol use and illicit drugs. Illicit drugs include marijuana/hashish, cocaine (including crack), heroin, hallucinogens, inhalants, or prescription-type psychotherapeutics used nonmedically. People may have a disorder for more than one substance.

SOURCE: National Survey on Drug Use and Health, 2010 (revised March 2012) and 2011 (revised May 2013), Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. See Appendix Table A-7 for detailed source information.

Figure 3-3 is a bar chart showing unemployment, past year arrest, current health, past year emergency room visits, and residential instability among adults by past year mental health and substance use disorder status for 2010 and 2011 combined. Current unemployment was 5.5% among adults with no mental illness or substance use disorder, 6.9% among adults with any mental illness only, 10.3% among adults with any substance use disorder only, and 12.4% among adults with co-occurring any mental illness and substance use disorder. Past year arrest was 1.5% among adults with no mental illness or substance use disorder, 2.2% among adults with any mental illness only, 12.6% among adults with any substance use disorder only, and 15.9% among adults with co-occurring any mental illness and substance use disorder. Fair or poor current health was 10.8% among adults with no mental illness or substance use disorder, 26.5% among adults with any mental illness only, 10.0% among adults with any substance use disorder only, and 21.6% among adults with co-occurring any mental illness and substance use disorder. Past year emergency room visits was 25.3% among adults with no mental illness or substance use disorder, 39.3% among adults with any mental illness only, 31.2% among adults with any substance use disorder only, and 44.7% among adults with co-occurring any mental illness and substance use disorder. Residential instability was 5.2% among adults with no mental illness or substance use disorder, 8.9% among adults with any mental illness only, 13.0% among adults with any substance use disorder only, and 20.2% among adults with co-occurring any mental illness and substance use disorder.

## 3.2 Children and Adolescents

### 3.2.1 Serious Emotional Disturbance and Levels of Impairment in Functioning

The term “serious emotional disturbance” was adopted by the federal government in 1993 to indicate a mental health disorder among children and adolescents that involves serious impairment that substantially interferes with or limits the child's role or functioning in family, school, or community activities (SAMHSA, 1993). Information about the prevalence of mental health disorders and related impairment among children and adolescents is available from a variety of studies. Data from NHANES indicate that 11 percent of children aged 8 to 11 experienced past year serious emotional disturbance and 12 percent of adolescents aged 12 to 15 experienced past year serious emotional disturbance (Merikangas et al., 2010a).

Findings from the NCS-A indicate that about 50 percent of adolescents aged 13 to 18 have experienced at least one mental health disorder in their lifetime (Merikangas et al., 2010b). Also, 22 percent of adolescents have experienced a lifetime disorder with severe impairment (Figure 3-4).

Figure 3-4 Lifetime prevalence of selected mental health disorder classes with and without severe impairment among adolescents aged 13 to 18: 2001−2004

^1^ Mood disorders include disorders such as bipolar disorder and major depressive disorder.

^2^ Anxiety disorders include disorders such as generalized anxiety and specific phobia.

^3^ Behavior disorders include disorders such as attention-deficit/hyperactivity disorder, conduct disorder, and oppositional defiant disorder.

SOURCE: National Comorbidity Survey–Adolescent Supplement, 2001–2004. See Appendix Table A-8 for detailed source information.

Figure 3-4 is a bar chart showing the lifetime prevalence of selected mental health disorder classes with and without severe impairment among adolescents aged 13 to 18 using data collected over the period from 2001 through 2004. Among adolescents aged 13 to 18, 14.3% had a mood disorder without serious impairment and 11.2% had a mood disorder with severe impairment; 31.9% had an anxiety disorder without severe impairment and 8.3% had an anxiety disorder with severe impairment; 19.6% had a behavior disorder without severe impairment and 9.6% had a behavior disorder with severe impairment; and 49.5% had any class of disorder without severe impairment and 22.2% had any class of disorder with severe impairment.

The impairment in functioning associated with serious emotional disturbance affects the ability of children or adolescents to achieve success at home, school, work, or in their communities. Indicators of impairment in functioning, such as arrest and school dropout, are higher among adolescents with serious emotional disturbance than among adolescents without serious emotional disturbance (Figure 3-5).

Figure 3-5 Lifetime prevalence of being arrested, dropping out of school, failing a grade, and spending time in a juvenile corrections facility among adolescents aged 13 to 18, by level of severity of emotional disturbance: 2001−2004

SOURCE: National Comorbidity Survey–Adolescent Supplement, 2001–2004. See Appendix Table A-9 for detailed source information.

Figure 3-5 is a bar chart showing the lifetime prevalence of being arrested, dropping out of school, failing a grade, and spending time in a juvenile corrections facility among adolescents aged 13 to 18 by level of severity of emotional disturbance using data collected over the period from 2001 through 2004. Among adolescents who had been arrested, 10.6% had emotional disturbance with low severity, 16.0% had emotional disturbance with moderate severity, and 20.3% had emotional disturbance with high severity. Among adolescents who had dropped out of school, 0.3% had emotional disturbance with low severity, 0.7% had emotional disturbance with moderate severity, and 3.3% had emotional disturbance with high severity. Among adolescents who had failed a grade, 15.8% had emotional disturbance with low severity, 21.0% had emotional disturbance with moderate severity, and 27.7% had emotional disturbance with high severity. Among adolescents who had spent time in a juvenile corrections facility, 0.3% had emotional disturbance with low severity, 2.1% had emotional disturbance with moderate severity, and 3.8% had emotional disturbance with high severity.

## 3.3 Summary

Adults with serious and persistent mental health disorders often experience impairment in carrying out day-to-day activities. Estimates from NSDUH indicate that approximately 4 percent of adults experience mental illness with serious impairment, which is often referred to as serious mental illness. People with serious mental illness are more likely than those who do not experience serious mental illness to also experience unemployment, a past year arrest, fair or poor health, and residential instability. Adults with serious mental illness are also more likely to be perpetrators and victims of interpersonal violence.

Among adults, the functional impairment associated with co-occurring mental health and substance use disorders is often more pronounced than impairment associated with either a mental health disorder or a substance use disorder alone. Specifically, co-occurring disorders are associated with less treatment adherence and poorer outcomes compared with a mental health disorder or substance use disorder alone.

Children and adolescents who experience a mental health or substance use disorder with serious impairment often experience related impairment in their day-to-day functioning. Adolescents with serious emotional disturbance are more likely than their peers to have dropped out of school, failed a grade in school, or spent time in a juvenile corrections facility. Impairment experienced at any time during the life span may be debilitating. This is especially true if the impairment is experienced during a critical developmental period, such as when a person is getting their education, getting their first job, or assuming a parenting role.

## 3.4 References

Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 2010. Web-based Injury Statistics Query and Reporting System (WISQARS). Retrieved from http://www.cdc.gov/injury/wisqars/index.html.
Choe JY, Teplin LA, Abram KM. Perpetration of violence, violent victimization, and severe mental illness: Balancing public health concerns. Psychiatric Services. 2008;59(2):153-164. [doi: 10.1176/appi.ps.59.2.153]. [pmid: 18245157].
Costello EJ, Compton SN, Keeler G, Angold A. Relationships between poverty and psychopathology: A natural experiment. Journal of the American Medical Association. 2003;290(15):2023-2029. [doi: 10.1001/jama.290.15.2023]. [pmid: 14559956].
Goodman LA, Salyers MP, Mueser KT, Rosenberg SD, Swartz M, Essock SM, et al., Swanson J. Recent victimization in women and men with severe mental illness: Prevalence and correlates. Journal of Traumatic Stress. 2001;14(4):615-632. [doi: 10.1023/A:1013026318450]. [pmid: 11776413].
Grant BF, Stinson FS, Dawson DA, Chou SP, Dufour MC, Compton W, Pickering RP, Kaplan K. Prevalence and co-occurrence of substance use disorders and independent mood and anxiety disorders: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. Archives of General Psychiatry. 2004;61(8):807-816. [doi: 10.1001/archpsyc.61.8.807]. [pmid: 15289279].
Herbeck DM, Fitek DJ, Svikis DS, Montoya ID, Marcus SC, West JC. Treatment compliance in patients with comorbid psychiatric and substance use disorders. The American Journal on Addictions. 2005;14(3):195-207. [doi: 10.1080/10550490590949488]. [pmid: 16019970].
Hiday VA, Swanson JW, Swartz MS, Borum R, Wagner HR. Victimization: A link between mental illness and violence?. International Journal of Law and Psychiatry. 2001;24(6):559-572. [doi: 10.1016/j.ijlp.2004.08.010]. [pmid: 11795220].
Kelly TM, Daley DC, Douaihy AB. Treatment of substance abusing patients with comorbid psychiatric disorders. Addictive Behavior. 2012;37(1):11-24. [doi: 10.1016/j.addbeh.2011.09.010].
Kessler RC. The epidemiology of dual diagnosis. Biological Psychiatry. 2004;56(10):730-737. [doi: 10.1016/j.biopsych.2004.06.034]. [pmid: 15556117].
Kessler RC, Chiu WT, Demler O, Merikangas KR, Walters EE. Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Archives of General Psychiatry. 2005;62(6):617-627. [doi: 10.1001/archpsyc.62.6.617]. [pmid: 15939839].
Merikangas KR, He JP, Brody D, Fisher PW, Bourdon K, Koretz DS. Prevalence and treatment of mental disorders among US children in the 2001– 2004 NHANES. Pediatrics. 2010;125(1):75-81. [doi: 10.1542/peds.2008-2598]. [pmid: 20008426].
Merikangas KR, He JP, Burstein M, Swanson SA, Avenevoli S, Cui L, et al., Swendsen J. Lifetime prevalence of mental disorders in U.S. adolescents: Results from the National Comorbidity Survey Replication—Adolescent Supplement (NCS-A). Journal of the American Academy of Child and Adolescent Psychiatry. 2010;49(10):980-989. [doi: 10.1016/j.jaac.2010.05.017]. [pmid: 20855043].
Scott KM, Von Korff M, Alonso J, Angermeyer MC, Bromet E, Fayyad J, et al., Williams D. Mental-physical co-morbidity and its relationship with disability: Results from the World Mental Health Surveys. Psychological Medicine. 2009;39(1):33-43. [doi: 10.1017/S0033291708003188]. [pmid: 18366819].
Substance Abuse and Mental Health Services Administration (SAMSHA). Final notice establishing definitions for (1) children with a serious emotional disturbance, and (2) adults with a serious mental illness. Federal Register. 1993;58:29422-29425.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2012. Results from the 2010 National Survey on Drug Use and Health: Mental health findings. DHHS Publication No. (SMA) 11-4667. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Tsai J, Stroup TS, Rosenheck RA. Housing arrangements among a national sample of adults with chronic schizophrenia living in the United States: A descriptive study. Journal of Community Psychology. 2011;39(1):76-88. [doi: 10.1002/jcop.20418].
World Health Organization. 2004. Changing history. Annex Table 3: Burden of disease in DALYs by cause, sex, and mortality stratum in WHO regions, Estimates for 2002 (pp A126–A127). Geneva. World Health Organization.