# BEHAVIORAL HEALTH DISORDERS ACROSS THE LIFE SPAN

Up to one-third of adults potentially meet the criteria for a past year behavioral health disorder (Kessler, Chiu, Demler, Merikangas, & Walters, 2005). Of those with a disorder, half report that their disorders were first experienced by age 14, and almost three-quarters report that their disorders were first experienced by age 24 (Kessler, Berglund, Demler, Jin, Merikangas, & Walters, 2005).

Behavioral health disorders—meaning mental health and substance use disorders—are common, recurrent, and often serious, but treatable. Importantly, different disorders have different ages at which symptoms tend to occur, get worse, or get better. Thus, understanding the onset, course, and prevalence of these disorders across the life span is an essential step in preventing, treating, and assisting in recovery.

This section reviews evidence on the onset and lifetime prevalence of mental health and substance use disorders for adolescents and adults. Among the data sources used are three prominent national studies: the National Comorbidity Survey Replication (NCS-R), the National Comorbidity Survey–Adolescent Supplement (NCS-A), and the National Survey on Drug Use and Health (NSDUH). For more information about these surveys, see Appendix B (Data Source Descriptions).

## 2.1 Onset and Prevalence of Mental Health Disorders

Certain disorders or classes of disorders are more likely to begin during particular times in life and are thus more prevalent in certain age groups. Among adolescents between the ages of 13 and 18, lifetime anxiety disorders (e.g., generalized anxiety disorder, specific phobia) are the most prevalent (31 percent) and have the earliest median age of first onset, usually around age 6. Behavior disorders (e.g., attention-deficit/hyperactivity disorder [ADHD], conduct disorder, oppositional defiant disorder) are present in approximately 19 percent of adolescents and are most likely to first appear around age 11. Mood disorders (e.g., bipolar disorder, major depressive disorder) are experienced by approximately 14 percent of adolescents and are most likely to first appear around age 13 (Merikangas et al., 2010) (Figures 2-1 and 2-2).

Figure 2-1 Cumulative lifetime prevalence of selected mental health disorder classes among children and adolescents, by age: 2001–2004

^1^ Mood disorders include disorders such as bipolar disorder and major depressive disorder.

^2^ Anxiety disorders include disorders such as generalized anxiety and specific phobia.

^3^ Behavior disorders include disorders such as attention-deficit/hyperactivity disorder, conduct disorder, and oppositional defiant disorder.

SOURCE: National Comorbidity Survey–Adolescent Supplement (NCS-A), 2001–2004. See Appendix Table A-1 for detailed source information.

Figure 2-1 is a line graph showing cumulative lifetime prevalence of selected mental health disorder classes among children and adolescents aged 4 to 18 using data collected over the period from 2001 through 2004. The percentages of children and adolescents with mood disorders are as follows: age 4 is 0%, age 5 is 0.38%, age 6 is 0.73%, age 7 is 1.29%, age 8 is 2.13%, age 9 is 2.82%, age 10 is 3.30%, age 11 is 4.45%, age 12 is 5.56%, age 13 is 7.79%, age 14 is 10.97%, age 15 is 13.32%, age 16 is 15.21%, age 17 is 17.27%, and age 18 is 18.14%. The percentages of children and adolescents with anxiety disorders is as follows: age 4 is 0%, age 5 is 8.84%, age 6 is 14.33%, age 7 is 17.74%, age 8 is 20.99%, age 9 is 22.79%, age 10 is 24.16%, age 11 is 25.79%, age 12 is 27.28%, age 13 is 29.20%, age 14 is 30.60%, age 15 is 31.57%, age 16 is 32.27%, age 17 is 32.99%, and age 18 is 33.43%. The percentages of children and adolescents with behavior disorders are as follows: age 4 is 0%, age 5 is 4.96%, age 6 is 7.01%, age 7 is 8.60%, age 8 is 9.66%, age 9 is 10.68%, age 10 is 11.31%, age 11 is 12.60%, age 12 is 13.96%, age 13 is 15.73%, age 14 is 17.75 percent, age 15 is 19.40%, age 16 is 20.31%, age 17 is 20.96%, and age 18 is 21.37%.

Figure 2-2 Lifetime prevalence of selected mental health disorder classes among adolescents, by age group: 2001–2004

^1^ Mood disorders include disorders such as bipolar disorder and major depressive disorder.

^2^ Anxiety disorders include disorders such as generalized anxiety and specific phobia.

^3^ Behavior disorders include disorders such as attention-deficit/hyperactivity disorder, conduct disorder, and oppositional defiant disorder.

SOURCE: National Comorbidity Survey–Adolescent Supplement (NCS-A), 2001–2004. See Appendix Table A-2 for detailed source information.

Figure 2-2 is a bar chart showing the prevalence of selected mental health disorder classes among adolescents by age group using data collected over the period 2001 through 2004. Among adolescents aged 13 to 14, 10.5% had mood disorders, 31.4% had anxiety disorders, and 18.2% had behavior disorders. Among adolescents aged 15 to 16, 15.5% had mood disorders, 32.1% had anxiety disorders, and 19.5% had behavior disorders. Among adolescents aged 17 to 18, 18.1% had mood disorders, 32.3% had anxiety disorders, and 21.9% had behavior disorders.

Not all mental health disorders first experienced during childhood or adolescence continue into adulthood, and not all mental health disorders are first experienced before adulthood. However, adults show a similar pattern of median age of first onset and lifetime prevalence to those reported by adolescents.

Among adults, anxiety disorders (e.g., generalized anxiety disorder, specific phobia) first appear the earliest, usually around age 11, and are the most prevalent (29 percent). Mood disorders (e.g., bipolar disorder, major depressive disorder) usually appear around age 30 and are the most prevalent class of lifetime disorder among adults between the ages of 30 and 44 (25 percent). Among adults aged 18 to 44, impulse control disorders (e.g., ADHD, oppositional defiant disorder) appear relatively early, around age 11, and are more prevalent among adults aged 18 to 29 (27 percent) than among adults aged 30 to 44 (23 percent) (Figure 2-3).

Figure 2-3 Lifetime prevalence of selected mental health disorder classes among adults, by age group: 2001–2003

^1^ Mood disorders include disorders such as bipolar disorder and major depressive disorder.

^2^ Anxiety disorders include disorders such as generalized anxiety and specific phobia.

^3^ Impulse control disorders include disorders such as attention-deficit/hyperactivity disorder and oppositional defiant disorder. Impulse control disorders were not assessed among adults aged 45 or older in this study.

NOTE: These disorder classes are different from those in Figures 2-1 and 2-2 because the data source reports on adults rather than adolescents.

SOURCE: National Comorbidity Survey Replication (NCS-R), 2001–2003. See Appendix Table A-3 for detailed source information.

Figure 2-3 is a bar chart showing the prevalence of selected mental health disorder classes among adults by age group using data collected over the period from 2001 through 2003. Among adults aged 18 to 29, 21.4% had mood disorders, 30.2% had anxiety disorders, and 26.8% had impulse control disorders. Among adults aged 30 to 44, 24.6% had mood disorders, 35.1% had anxiety disorders, and 23.0% had impulse control disorders. Among adults aged 45 to 59, 22.9% had mood disorders and 30.8% had anxiety disorders; impulse control disorders were not assessed among this age group. Among adults aged 60 or older, 11.9% had mood disorders and 15.3% had anxiety disorders; impulse control disorders were not assessed among this age group.

It is important to note that the major mental health surveys discussed above do not provide information about several types of severe but rare disorders, including schizophrenia and pervasive developmental disorders (e.g., autistic disorder). National epidemiological studies have generally not included formal assessments of these disorders, because of the challenges in accurately assessing symptoms outside of the clinic setting. Schizophrenia occurs in about 1 percent of the population and usually appears between the ages of 20 and 30 (American Psychiatric Association, 2000). Estimates of the prevalence rates of pervasive developmental disorders have varied. One recent estimate, based on data collected from 2006 to 2008, indicates that the prevalence of autism was 0.74 percent (Boyle et al., 2011).

People whose disorder begins earlier rather than later in life are more likely to experience the disorder in adulthood and have more severe symptoms. This has been found for depression, for example (Dekker, Ferdinand, van Lang, Bongers, van der Ende, & Verhulst, 2007; Pettit, Lewinsohn, Roberts, Seeley, & Monteith, 2009). As adults, people with early onset are more likely to experience suicidal symptoms, and their depression is likely to last longer (Korczak & Goldstein, 2009). A study of U.S. college students found that among students who reported symptoms consistent with a mental health diagnosis, more than half (60 percent) continued to report the same level of symptoms 2 years later (Zivin, Eisenberg, Gollust, & Golberstein, 2009).

## 2.2 Onset and Prevalence of Substance Use Disorders

About 11 percent of 13- to 18-year-olds have met the criteria for a lifetime alcohol or illicit drug use disorder. For adolescents, these disorders are most likely to appear around age 15. For adults, substance use disorder onset is about 20 years of age (Kessler, Berglund, et al., 2005).

Prevalence of substance use disorders increases during adolescence. Between the ages of 13 and 14, approximately 4 percent of youth meet the criteria for a substance use disorder. The rate increases to 12 percent for those aged 15 and 16 and then to 22 percent for those aged 17 and 18 (Merikangas et al., 2010).

Until adults reach the age of 60, the prevalence of substance use disorders remains relatively constant; approximately 17 percent of adults aged 18 to 29, 18 percent of adults aged 30 to 44, and 15 percent of adults aged 45 to 59 meet the criteria. However, the prevalence of substance use disorder drops to about 6 percent for adults aged 60 or older.

Research has shown that early initiation of substance use increases the risk for subsequent substance use disorder (e.g., Behrendt, Wittchen, Höfler, Lieb, & Beesdo, 2009). Figure 2-4 shows the average age of first alcohol and illicit drug use among those who initiated use in the past year. Although there is some variation across years and substances, the average age for initiating all substances was younger than 20 years.

Figure 2-4 Average age at first use among past year alcohol and illicit drug use initiates aged 12 to 49: 2007–2011

^1^ Illicit drugs include marijuana/hashish, cocaine (including crack), heroin, hallucinogens, inhalants, or prescription-type psychotherapeutics used nonmedically.

SOURCE: National Survey on Drug Use and Health, 2007–2011. See Appendix Table A-4 for detailed source information.

Figure 2-4 is a bar chart showing the average age at first use among past year alcohol and illicit drug use initiates aged 12 to 49 from 2007 through 2011. The average age of first use of alcohol was 16.8 years in 2007, 17.0 years in 2008, 16.9 years in 2009, 17.1 years in 2010, and 17.1 years in 2011. The average age of first use of illicit drugs was 18.0 years in 2007, 18.8 years in 2008, 17.6 years in 2009, 19.1 years in 2010, and 18.1 years in 2011.

As was true for mental health disorders, early onset of substance use disorders is associated with an increased risk of incarceration (Slade, Stuart, Salkever, Karakus, Green, & Ialongo, 2008), development of multiple substance use disorders (Bakken, Landheim, & Vaglum, 2004), and early mortality (Clark, Martin, & Cornelius, 2008).

## 2.3 Summary

Certain classes of disorders are more likely to begin during particular times in life. For example, anxiety disorders such as generalized anxiety or specific phobia tend to be first experienced at an earlier age than other classes of disorders. While not all mental health disorders experienced during childhood or adolescence continue into adulthood, early onset of a mental health or substance use disorder is associated with more severe symptoms and a chronic course of the disorder. Notably, many of the disorders that have been reviewed often co-occur with other disorders. The co-occurrence of disorders is prevalent and persistent across childhood, adolescence, and adulthood. Co-occurring disorders are discussed in more depth in Section 3.

## 2.4 References

American Psychiatric Association. 2000. Diagnostic and statistical manual of mental disorders. 4th ed., text rev. Washington, DC. American Psychiatric Association.
Bakken K, Landheim AS, Vaglum P. Early and late onset groups of substance misusers: Differences in primary and secondary psychiatric disorders. Journal of Substance Use. 2004;9(5):224-234. [doi: 10.1080/14659890410001711706].
Behrendt S, Wittchen HU, Höfler M, Lieb R, Beesdo K. Transitions from first substance use to substance use disorders in adolescence: Is early onset associated with a rapid escalation?. Alcohol and drug Dependence. 2009;99(1-3):68-78. [doi: 10.1016/j.drugalcdep.2008.06.014].
Boyle CA, Boulet S, Schieve LA, Cohen RA, Blumberg SJ, Yeargin-Allsopp M, et al., Kogan MD. Trends in the prevalence of developmental disabilities in US children, 1997–2008. Pediatrics. 2011;127(6):1034-1042. [doi: 10.1542/peds.2010-2989]. [pmid: 21606152].
Clark DB, Martin CS, Cornelius JR. Adolescent-onset substance use disorders predict young adult mortality. Journal of Adolescent Health. 2008;42(6):637-639. [doi: 10.1016/j.jadohealth.2007.11.147]. [pmid: 18486875].
Dekker MC, Ferdinand RF, van Lang ND, Bongers IL, van der Ende J, Verhulst FC. Developmental trajectories of depressive symptoms from early childhood to late adolescence: Gender differences and adult outcome. Journal of Child Psychology and Psychiatry. 2007;48(7):657-666. [pmid: 17593146].
Kessler RC, Berglund P, Demler O, Jin R, Merikangas KR, Walters EE. Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Archives of General Psychiatry. 2005;62(6):593-602. [pmid: 15939837].
Kessler RC, Chiu WT, Demler O, Merikangas KR, Walters EE. Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Archives of General Psychiatry. 2005;62(6):617-627. [pmid: 15939839].
Korczak DJ, Goldstein BI. Childhood onset major depressive disorder: Course of illness and psychiatric comorbidity in a community sample. Journal of Pediatrics. 2009;155(1):118-123. [doi: 10.1016/j.jpeds.2009.01.061]. [pmid: 19394039].
Merikangas KR, He JP, Burstein M, Swanson SA, Avenevoli S, Cui L, et al., Swendsen J. Lifetime prevalence of mental disorders in U.S. adolescents: Results from the National Comorbidity Survey Replication–Adolescent Supplement (NCS-A). Journal of the American Academy of Child and Adolescent Psychiatry. 2010;49(10):980-989. [doi: 10.1016/j.jaac.2010.05.017]. [pmid: 20855043].
Pettit JW, Lewinsohn PM, Roberts RE, Seeley JR, Monteith L. The long-term course of depression: Development of an empirical index and identification of early adult outcomes. Psychological Medicine. 2009;39(3):403-412. [doi: 10.1017/S0033291708003851]. [pmid: 18606049].
Slade EP, Stuart EA, Salkever DS, Karakus M, Green KM, Ialongo N. Impacts of age of onset of substance use disorders on risk of adult incarceration among disadvantaged urban youth: A propensity score matching approach. Alcohol and drug Dependence. 2008;95(1-2):1-13. [doi: 10.1016/j.drugalcdep.2007.11.019].
Zivin K, Eisenberg D, Gollust SE, Golberstein E. Persistence of mental health problems and needs in a college student population. Journal of Affective Disorders. 2009;117(3):180-185. [doi: 10.1016/j.jad.2009.01.001]. [pmid: 19178949].