# INTRODUCTION

Behavioral Health, United States, 2012 serves as the Nation's most comprehensive resource for statistics on mental health and substance use. For more than 25 years, the Mental Health, United States series has presented the leading indicators of the prevalence of mental health disorders and the use and financing of treatment in the United States.

The current volume has changed in several ways from the previous volume. The biggest change is that estimates related to substance use—such as alcohol misuse and illicit drug use—have been added to the estimates related to mental health. The term “behavioral health” encompasses both mental health and substance use, and thus the title of the volume has been changed to Behavioral Health, United States, 2012. Including estimates related to substance use is important because of the large number of people who experience both mental health and substance use disorders in their lifetime. Nearly 9 million people are estimated to have both types of behavioral health disorders (Substance Abuse and Mental Health Services Administration [SAMHSA], 2013). The larger perspective on behavioral health will help strengthen the series' utility as a key resource for decision making in a changing and challenging health care landscape.

## 1.1 About This Volume

This volume is organized into five sections. Section 1 provides an introduction to the report; summarizes the numerous changes from the previous volume, Mental Health, United States, 2010; and explains the implications of health care reform under the Affordable Care Act. Sections 2 through 4 provide analytic text on three important behavioral health topics: the course and prevalence of behavioral health disorders over people's lives, the degree to which behavioral health conditions may affect an individual's daily functioning, and key issues regarding behavioral health treatment. Section 5 presents 172 detailed reference tables from 45 sources that address the prevalence of mental health and substance use disorders; the number of people treated for those disorders; the number of beds, providers, and facilities in which treatment is offered; and spending on treatment.

## 1.2 Additions to Data in This Volume

As noted above, this volume adds substance use data to the mental health data that have been the focus of this series. Also, this volume attempts to address some of the data gaps identified in previous years by using new or recently identified sources. Of particular note, the reference tables in Section 5 now include more data on children; vulnerable populations; military personnel, veterans, and military families; Medicaid beneficiaries; and the behavioral health treatment workforce.

### 1.2.1 Children

This volume presents expanded national estimates on behavioral health disorders among children. Despite this improvement in the volume, limited data are available on the prevalence of and treatment for behavioral health problems for children younger than age 6. No national study has been conducted on behavioral health problems among young children. To gather accurate data on children, surveys require a large number of interviewers who are highly trained. The difficulty and expense of such surveys are possible reasons why a data gap remains on the behavioral health of young children.

### 1.2.2 Vulnerable Populations

This volume includes available national data on behavioral health measures for several populations, such as people with behavioral health disorders who are living in nursing homes, seeking shelter in homeless shelters, and living in various institutional settings, such as jails. Despite the expanded data on these vulnerable populations in this volume, some improvements in the data are recommended. For example, data on the behavioral health of people who are homeless come from a survey of homeless shelter staff who report the proportion of clients at their shelter with behavioral health conditions. This approach to gathering data is likely not as accurate as other approaches used to gather data on behavioral health for the general population, such as directly interviewing individuals or household members, obtaining reports from trained medical providers, or gathering administrative billing data.

### 1.2.3 Military Personnel, Veterans, and Military Families

Data are needed to help support treatment and services for those who are serving or have served in the armed forces and their families. The current volume includes several recent tables of estimates on the behavioral health needs and treatment of these populations. For the first time in the series, for example, this volume provides estimates on the behavioral health needs of Army spouses seeking treatment.

### 1.2.4 Medicaid Beneficiaries

Medicaid is an insurance program for people with low incomes. It is a key funding source for behavioral health treatment because a disproportionate number of low-income individuals have behavioral health conditions (e.g., Han, Clinton-Sherrod, Gfroerer, Pemberton, & Calvin, 2010). Because Medicaid is such an important funding source for services, timely national data are needed on the behavioral health treatment provided through Medicaid and the characteristics of treatment recipients. For example, to help provider agencies budget for services under Medicaid, data are needed on the cost of treatment. This volume presents recent national estimates of spending on Medicaid behavioral health treatment.

### 1.2.5 Treatment Workforce

Data on the behavioral health treatment workforce are critical to decision makers working to ensure that enough care of the right type is available to people who want it. To plan appropriately for services, the data should span a sufficiently large range of service providers. This volume presents data on the main types of staff providing behavioral health services. The equivalent data for staff providing substance abuse services are limited, however. National data are only available for a small number of the many types of staff providing substance abuse services.

## 1.3 How Data in This Volume Improve Understanding of the Impact of Health Care Reform on Behavioral Health Treatment

Much of the data in this volume may help support ongoing health care reform efforts under the Affordable Care Act (ACA).^1^ At the time of writing, health care reform is under way and will make some important demands on behavioral health data.

1 The ACA comprises two legislative acts passed in 2010: the Patient Protection and Affordable Care Act (Public Law 111-148) and the Health Care and Education Reconciliation Act of 2010 (Public Law 111-152).

The ACA will greatly expand the number of people who will be insured. Those who are newly insured will have to pay less to get health care and so may be more likely to seek care. This volume provides data that will help support behavioral health service planning in the face of such large-scale changes.

The data in this volume complement other emerging data sources for understanding the impact of the ACA. Health care reform has helped stimulate many other large-scale efforts to further improve data on treatment capacity, utilization, and its payment. At the time of writing, many of these efforts—such as a project that is creating a Multi-Payer Claims Database—are ongoing. These new efforts present an exciting opportunity to address many of the remaining gaps in data on behavioral health.

Behavioral health and its treatment have some distinguishing features that are particularly affected by the ACA. This volume improves the understanding on this topic in several ways. The following are four selected examples.

### 1.3.1 Helping Ensure Parity in Coverage between Behavioral Health Conditions and Other Medical Conditions

Before recent legislation such as the ACA, insurers could offer more limited coverage for behavioral health conditions than for other medical conditions (e.g., by allowing fewer visits to a specialist) or not offer behavioral health coverage at all. The ACA and other recent legislation have helped ensure parity by requiring that insurers cover behavioral health disorders and that the coverage is similar to coverage for other medical conditions. The text describing the treatment landscape (Section 4) and the reference tables (Section 5) provide a wealth of data on treatment before the ACA goes into effect.

### 1.3.2 Covering More People through Medicaid

Medicaid—public insurance for some categories of low-income people—plays an important role in behavioral health provision. For example, Medicaid accounts for a far higher share of spending on mental health (about 30 percent) than all health in general (about 16 percent) (SAMHSA, 2010, 2012). Such coverage is particularly important for people whose behavioral health condition is so serious that it greatly affects their day-to-day lives (see Section 3 on serious impairment).

The ACA will make Medicaid even more critical to addressing behavioral health problems. In 2014, by the time this volume is published, some states will have elected to increase the number of people covered by Medicaid, by extending coverage to low-income childless adults. The result is that more than 2 million people who did not use services previously are projected to seek mental health services because they will be newly covered by Medicaid (Garfield, Zuvekas, Lave, & Donohue, 2011). A similarly large number of people may seek substance abuse treatment because of the Medicaid expansion (Busch, Meara, Huskamp, & Barry, 2013). The data in this volume provide detailed information on the prevalence of behavioral health conditions among people covered by Medicaid, spending on Medicaid services, and optional behavioral health services that are covered by Medicaid in each state.

### 1.3.3 Reducing Barriers for People with Pre-Existing Conditions

In 2010, the ACA created special insurance pools that enabled adults with pre-existing conditions to buy insurance. This provision of the Act is important because many behavioral health disorders have long-lasting effects, and treatment may be needed over the course of several years. A pre-existing condition clause in insurance is often a barrier to receiving treatment in one year if someone got treatment for the same condition the previous year: under such a clause, that person might be ineligible to enroll for an insurance program the next year, for example. Or, if that person could enroll the next year, the insurance program may not cover treatment for the behavioral health condition. The ACA thus helps more people get their behavioral health treatment covered by insurance.

This volume provides many reference tables (Section 5) and analytic text (see Section 2) on the prevalence and treatment of behavioral health conditions and disorders throughout people's development, from childhood through adulthood. However, as Section 2 notes, national data are needed that track the behavioral health conditions and treatment of people over time. Such data could be used to track the degree to which provisions in the ACA help people recover from and cope with behavioral health disorders.

### 1.3.4 Improving Access to Prescription Medication for Treatment of Behavioral Health Conditions

Prescription medications are an important resource for treating behavioral health conditions, particularly for treating mental health conditions. These medications account for nearly 30 percent of all mental health treatment spending and nearly 4 percent of substance abuse spending (SAMHSA, 2010). The ACA placed limits on the amount people are required to spend out-of-pocket on these medications. These new limits may reduce the financial burden of prescription medication and therefore may increase the number of people who can afford the needed treatment. This volume presents estimates on the use of and expenditures on prescription medication for mental health disorders.

## 1.4 Summary

Adding data on substance use to the set of mental health data presented in previous editions has greatly increased the scope and utility of this volume. Moreover, many of the tables in this volume address previously identified data gaps. Improved behavioral health data are included on children; vulnerable populations; military personnel, veterans, and military families; Medicaid beneficiaries; and the behavioral health treatment workforce.

Reforms to the health care system under the ACA require data for many purposes, such as projecting behavioral health treatment needs and capacity. This volume promises to be a critical source for these purposes by compiling the data, standardizing the measures, and presenting the data in an accessible way for many people, including treatment providers, policy makers, and researchers. The volume is thus an important resource for helping to understand and reduce the impact of mental illness and substance abuse on the Nation's communities.

## 1.5 References

Busch SH, Meara E, Huskamp HA, Barry CL. Characteristics of adults with substance use disorders expected to be eligible for Medicaid under the ACA. Psychiatric Services. 2013;64(6):520-526. [doi: 10.1176/appi.ps.201200011]. [pmid: 23450343].
Garfield RL, Zuvekas SH, Lave JR, Donohue JM. The impact of national health care reform on adults with severe mental disorders. American Journal of Psychiatry. 2011;168(5):486-494. [doi: 10.1176/appi.ajp.2010.10060792]. [pmid: 21285138].
Han B, Clinton-Sherrod AM, Gfroerer J, Pemberton MR, Calvin SL. 2010. State and sociodemographic variations in substance use treatment need and receipt in the United States. CBHSQ data review. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2010. National expenditures for mental health services & substance abuse treatment, 1986–2005. DHHS Publication No. (SMA) 10-4612. Rockville, MD. Center for Mental Health Services and Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration. Retrieved from http://store.samhsa.gov/shin/content/SMA10-4612/SMA10-4612.pdf.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2012. Mental Health, United States, 2010. DHHS Publication No. (SMA) 12-4681. Rockville, MD. Substance Abuse and Mental Health Services Administration. Retrieved from http://www.samhsa.gov/data/2k12/MHUS2010/MHUS-2010.pdf.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2013. Co-occurring disorders: Rates of co-occurring mental and substance use disorders. Retrieved from http://www.samhsa.gov/co-occurring/topics/data/disorders.aspx.