# BEHAVIORAL HEALTH, UNITED STATES, 2012 EXPERT ADVISORY PANEL

The structure and content of the report were guided by the suggestions of an Expert Advisory Panel that was convened on March 6, 2012:

Panel Member | Affiliation
Kirsten Beronio | Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services
Jeffrey Buck | Centers for Medicare & Medicaid Services
Lisa Colpe | National Institute of Mental Health
Peter Delany | Substance Abuse and Mental Health Services Administration
Sarah Duffy | National Institute on Drug Abuse
William Eaton | Johns Hopkins University, Department of Mental Health
Rachel Garfield | Kaiser Commission on Medicaid and the Uninsured
Lauren Glaze | Bureau of Justice Statistics
Darcy Gruttadaro | National Alliance on Mental Illness
Kevin Hennessy | Substance Abuse and Mental Health Services Administration
Bradley Karlin | Veterans Administration
Sharon Larson | Substance Abuse and Mental Health Services Administration
Danyelle Mannix | Substance Abuse and Mental Health Services Administration
Charlotte Mullican | Agency for Healthcare Research and Quality
Peggy Murray | National Institute on Alcohol Abuse and Alcoholism
Mark Olfson | Columbia University, Department of Psychiatry
John Park | Substance Abuse and Mental Health Services Administration
Alexander Ross | Health Resources and Services Administration
Michael Schoenbaum | National Institute of Mental Health
David Shern | Mental Health America
Catherine Simile | Centers for Disease Control and Prevention
Rita Vandivort-Warren | Health Resources and Services Administration
Mohini Venkatesh | National Council for Community Behavioral Healthcare