# GLOSSARY

Behavioral health: A state of mental/emotional being and/or choices and actions that affect wellness. Behavioral health problems include substance abuse or misuse, alcohol and drug addiction, serious psychological distress, suicide, and mental and substance use disorders.
Block Grant: The Substance Abuse and Mental Health Services Administration (SAMHSA) administers three Block Grant programs for mental health treatment, substance abuse prevention, and substance abuse treatment. The grants are allocated by formula—rather than by discretionary criteria, for example—among states and territories. Funds are for prevention, treatment, recovery supports, and other services that will supplement services covered by Medicaid, Medicare, and private insurance. Congress determines the total level of funds available.
Children's Health Insurance Program (CHIP): A program by which states insure low-income children (aged 19 or younger) who are ineligible for Medicaid but whose families cannot afford private insurance. States receive federal matching dollars to help provide for this coverage.
Child welfare system: The social service system that receives and investigates reports of possible child abuse and neglect; provides services to families that need assistance in the protection and care of their children; arranges for children to live with kin or with foster families when they are not safe at home; and arranges for reunification, adoption, or other permanent family connections for children leaving foster care.
Clubhouse: An organization hosting a specific model of care that helps people with mental illness participate in the broader community. A clubhouse provides members an array of nonmedical services, many of which focus on education and employment. Members themselves often participate in service provision.
Community health center: An organization that serves populations with limited access to health care, usually because of limited financial resources. These centers are public and private nonprofit health care organizations that meet certain criteria under the Medicare and Medicaid programs.
Community hospital: Any non-federal, short-term general or other specialty hospital, including academic medical centers or other teaching hospitals that are non-federal short-term hospitals. The term typically excludes hospitals not accessible by the general public, such as prison hospitals or college infirmaries. See also general hospital.
Complementary and alternative medicine: A broad class of services that are not traditionally provided as billable services in the treatment system. Includes services from several types of healers, participation in an Internet support group, or participation in a self-help group. The most commonly used complementary and alternative medicine services are those from spiritual advisors, relaxation techniques, and use of multivitamins and herbs.
Counselor: A certified professional offering therapy and aiding clients who are distressed with behavioral health problems.
Crisis services: Services addressing mental health or substance use problems that require immediate attention. Includes assessing needs and providing short-term intervention, referral to treatment, and linkage to support services (e.g., meals on wheels).
Day treatment or partial hospitalization: A program of services used to treat mental illness or substance use disorders. The patient continues to live at home and travels to a treatment center up to 7 days per week. Focuses on the overall treatment of the person and is intended to avert or reduce inpatient hospitalization.
Detoxification: Refers to the medical management of symptoms of withdrawal. Detoxification, or detox, is not considered definitive treatment and often complements outpatient or residential substance abuse treatment.
Drug court: A special court with jurisdiction over cases involving drug-using offenders. These courts often manage cases through comprehensive supervision, drug testing, treatment services, and immediate sanctions and incentives.
Dual eligibility: When someone qualifies for both Medicare and Medicaid insurance coverage. Medicare is federally funded health insurance for people aged 65 or older and for certain younger people with disabilities. Medicaid is health insurance for people requiring financial assistance and is jointly funded by the federal government and the states.
Emergency department: A section of an institution that is staffed and equipped to provide immediate care, particularly for sudden, acute illness and trauma.
Emotional disturbance: An emotional or behavioral health condition that prevents a child or adolescent from performing everyday tasks. This condition is characterized by an inability to build or maintain relationships, inappropriate behaviors or feelings under normal circumstances, a pervasive mood of unhappiness or depression, or a tendency to develop physical symptoms or fears related to personal or school problems.
Family preservation worker: A professional facilitating or providing services usually for a child so that the child can remain with the family rather than be placed out of his or her home. Services are often provided at the child's home.
Family therapy: A number of therapies that serve the family as a whole.
Functional impairment: A level of disability or distress in daily life that is attributable to symptoms of mental illness.
General hospital: A community medical/ surgical or specialty hospital (other than a mental health and substance abuse specialty hospital) providing diagnostic and medical treatment to inpatients, including inpatient psychiatric care in a specialized treatment unit of a general hospital and other mental health treatment services. See also community hospital.
General medical setting: A location where medicine or surgery across any number of disciplines is practiced.
Group home: A private residence for people with behavioral health problems. The number of residents may be limited, and often a trained caregiver is at the home at all times.
Group therapy: Care for behavioral health disorders provided to groups of patients.
Health maintenance organization (HMO): A type of managed care organization that provides a variety of services. Typically, services are provided for a set flat fee per patient. In some HMOs, a primary care provider directs access to other medical services. Usually, providers agree to treat patients in accordance with the HMO's guidelines and restrictions.
Home health care: A set of services provided in the patient's residence by private and public freestanding agencies or home health agencies. Freestanding means that the agency is not based in a hospital, nursing home, or other type of provider whose primary mission is something other than home health services.
Hospice: A form of care that provides palliative and supportive care services, including physical, psychological, social, and spiritual care for dying persons, their families, and other loved ones. Hospice services are available in home and inpatient settings.
Illicit drug: A broad class of substance that is taken for nonmedical purposes or is illegally sold or consumed. Depending on the data source, this class of substance often includes, but is not limited to, marijuana, cocaine (including crack), heroin, hallucinogens, inhalants, methamphetamine, and prescription-type psychotherapeutics.
Inpatient: Care provided in an acute medical care unit, usually a hospital, and treatment typically requires an overnight stay.
Insurance administration: The set of activities used to run health care insurance programs.
Intensive outpatient program: Intensive outpatient programs serve as an intermediate level of care for patients who have needs that are too complex for outpatient treatment but do not require inpatient services. These programs allow people to continue with their daily routine and practice newly acquired recovery skills both at home and at work.
Medicaid: A program jointly funded by federal and state governments that provides health care coverage to certain classes of people with limited income and resources. Within federal guidelines, state governments set eligibility standards, determine optional services provided, set reimbursement rates, and administer the program. Income and resources are only two factors in determining eligibility, so not all people with limited income in a state are necessarily covered by this program.
Medicare: A federal government program that provides health insurance coverage to eligible adults aged 65 or older and people with disabilities. It has four parts: Part A, which covers institutional services, including inpatient hospital services, nursing home care, initial home health visits, and hospice care; Part B, which covers physicians and other professional services, outpatient clinic or hospital services, laboratory services, rehabilitation therapy, and home health visits not covered by Part A, among other services; Part C, the Medicare Advantage program, which is managed by private companies for a flat fee per patient per month; and Part D, which began in 2006 and covers medication.
Mental illness: A set of conditions that disrupt thinking, feeling, mood, relationships with others, or functioning on a day-to-day basis. Measurement of mental illness and the specific categories of illness depend on the data source. Most sources reference the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) or the ninth or tenth editions of the International Classification of Diseases (ICD-9 and ICD-10).
Mental health treatment: Health care provided through prescription medication, or outpatient or inpatient care for problems with emotions, nerves, or mental health.
Mood disorder: A collection of disorders where a disturbance of mood is the main underlying feature. Includes depressive or bipolar disorders as defined in the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV).
Nursing home care: A set of services provided in private and public freestanding nursing home facilities. Freestanding means that the nursing home is not based in a hospital or other type of provider whose primary mission is something other than nursing home care. The facility includes nursing and rehabilitative services, generally for an extended period of time by staff of registered or licensed practical nurses with physician consultation or oversight.
Out-of-pocket payment: Direct expenditure by consumers for health care goods and services, including coinsurance, deductibles, and any amounts paid for health care services that are not covered by insurance. Depending on the data source, health insurance premiums may or may not be included.
Outpatient: Care provided in an ambulatory setting, and treatment does not require an overnight stay. Unless otherwise specified, this setting may include a hospital outpatient department; an emergency room; physician's or other medical professional's (private therapist, psychologist, psychiatrist, social worker, or counselor) office or clinic; mental health clinic or center; partial day hospital or day treatment program; and in-home therapist, counselor, or family preservation worker.
Parity: A term applied to health insurance, meaning that coverage for behavioral health care is similar in scope and quantity to coverage for other medical conditions.
Prescription medication: A medication available through primary or specialty providers; retail outlets, such as community pharmacies; pharmacies in mass merchandise stores, grocery stores, and department stores; mail order pharmacies; hospitals; exclusive-to-patient health maintenance organizations; and nursing home pharmacies.
Primary diagnosis: The main or principal diagnosis that most typically has led to the admission of an individual to a hospital or to receipt of outpatient treatment. In an outpatient care setting, the condition may be referred to as the first-listed diagnosis. In an inpatient setting, the condition may be the most serious and/or resource-intensive during that hospitalization.
Private health insurance: Third-party coverage not provided by government sources.
Psychiatric hospitals: Facilities that typically specialize in treating people with serious mental illness and vary widely in their size and function. Many specialize in the temporary or permanent care of residents who require routine assistance, treatment, or a controlled environment.
Psychiatrist: Independently billing private or group practice of health practitioners having the degree of M.D. or D.O. who are primarily engaged in the practice of psychiatry or psychoanalysis.
Psychologist: A person trained and educated to perform psychological research, testing, and therapy.
Prescription Drug Monitoring Program (PDMP): A statewide electronic database that collects designated data on substances dispensed in the state. The PDMP is managed and housed by a specified statewide agency.
Rehabilitation: Services and treatment focused on a person recovering from or coping with symptoms to function in society. When applied to substance use, the intent is to cease substance abuse and thus avoid its social consequences.
Residential services: Services provided in a 24-hour care setting that provides therapeutic care to patients using licensed behavioral health professionals.
Retail prescription drug or retail prescription medication: Prescription medication that excludes prescription drugs sold through hospitals, exclusive-to-patient health maintenance organizations, or nursing home pharmacies.
Scatter bed: A general medical bed in a hospital dedicated to providing inpatient psychiatric care. Psychiatric care in scatter beds may occur even in hospitals with separate psychiatric units.
Serious mental illness: Among adults aged 18 or older, defined as having a diagnosable mental, behavioral, or emotional disorder (excluding developmental and substance use disorders) that has resulted in serious functional impairment, which substantially interferes with or limits one or more major life activities. Estimates of serious mental illness are provided annually in the National Survey on Drug Use and Health.
Serious psychological distress: The presence of mental health symptoms in the past 30 days that may negatively affect an adult's ability to participate in family, community, and work life. Serious psychological distress is not a diagnosis and does not represent a specific mental disorder. This construct is measured annually in the National Health Interview Survey.
Specialty hospital: A hospital that provides behavioral health services to the majority of its patients.
State Mental Health Agency: A state government organization responsible for directing resources for people in need of mental health services. For example, a state Mental Health Agency typically applies for and administers federal Mental Health Block Grant funding for its state.
State Substance Abuse Agency: A state government organization responsible for directing resources for people in need of substance abuse services. For example, a state Substance Abuse Agency typically applies for and administers federal Substance Abuse Block Grant funding for its state.
Substance abuse: A pattern of substance use that leads to clinically significant impairment and includes symptoms such as failure to fulfill major role obligations, legal problems, use in situations that are physically hazardous, and continued use despite persistent social or interpersonal problems.
Substance abuse medication: Medication used to treat substance use disorders, often used to ease withdrawal symptoms, prevent relapse, diminish cravings, and restore normal brain function.
Substance abuse treatment: Health care to reduce or stop alcohol or illicit drug use or for medical problems associated with alcohol or illicit drug use.
Substance dependence: A pattern of substance use that leads to clinically significant impairment and includes symptoms such as drug taking in larger amounts than intended, inability to cut down on drug use, a great deal of time spent on activities necessary to obtain the drug, and continued use despite knowledge of health or social problems caused by the drug.
Substance use disorder: Disorder characterized by continued use of a medication or a non-medically indicated drug or toxin, resulting in repeated adverse social consequences related to use of the substance. Social consequences include failing to meet work or school obligations, poor relationships with family, interpersonal conflicts, and legal problems. The main disorder categories are substance abuse and substance dependence. Substance abuse is typically defined in terms of the social consequences of substance use, and substance dependence is typically defined by physiological and behavioral symptoms of substance use. Measurement depends on the data source. Many sources reference the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) or the ninth or tenth editions of the International Classification of Diseases (ICD-9 and ICD-10).
Therapist: A certified professional offering therapy and aiding clients who are distressed with behavioral health problems.
U.S. Department of Veterans Affairs (VA): A government-run benefit system for people who have served in the military. Benefits include health care, which is administered by the Veterans Health Administration.
Veterans Health Administration: The medical assistance component of the U.S. Department of Veterans Affairs.