# DATA SOURCE DESCRIPTIONS

Data Source (Organization) | Description
CMS Minimum Data Set 3.0 (Centers for Medicare & Medicaid Services) | The Minimum Data Set (MDS) is part of the federally mandated process for clinical assessment of all residents in Medicare or Medicaid certified nursing facilities. MDS assessment forms are completed for all residents in certified nursing facilities, regardless of source of payment for the individual resident. MDS assessments are required for residents on admission to the nursing facility and then periodically, within specific guidelines and time frames. Data used in this volume were obtained for the fourth quarter of 2011 and 2012. You can find more information here: http://www.cms.gov/Research-Statistics-Data-and-Systems/Computer-Data-and-Systems/Minimum-Data-Set-3-0-Public-Reports/index.html
Continuum of Care Applications (U.S. Department of Housing and Urban Development) | The Continuum of Care Applications provide a point-in-time count of sheltered and unsheltered homeless people from either the last biennial count or a more recent annual count. Of note are the counts of people who are chronically homeless, people with severe mental illness, chronic substance abusers, veterans, people with HIV/AIDS, victims of domestic violence, and unaccompanied children. Data used in this volume were collected from 2006 through 2010. You can find more information here: http://portal.hud.gov/hudportal/HUD?src=/program_offices/comm_planning/homeless/programs/coc
Decision Support System (Veterans Health Administration) | The Veterans Health Administration Decision Support System is a managerial cost accounting system that interacts with the U.S. Department of Veterans Affairs' (VA) national databases to provide estimates of the cost of individual VA hospital stays and health care encounters. Data used in this volume were obtained for 2008 through 2012. You can find more information here: http://www.ncbi.nlm.nih.gov/pubmed/17102226
Defense Medical Surveillance System (Armed Forces Health Surveillance Center) | The Defense Medical Surveillance System collects medical records data from all individuals served by military medical facilities and from billing records for TRICARE-enrolled dependent claims data. Data used in this volume include 6,585,224 outpatient visits by 250,626 Army wives recorded in the Defense Medical Surveillance System. Data include all outpatient medical visits between January 1, 2003, and December 31, 2006, by wives of active duty Army personnel who either received outpatient care at a U.S. military treatment facility or used military medical insurance for an outpatient medical visit at a nonmilitary health care facility. You can find more information here: http://www.ncbi.nlm.nih.gov/pubmed/12453804
Department of Defense Survey of Health Related Behaviors Among Active Duty Military Personnel (U.S. Department of Defense) | The 2008 Department of Defense Survey of Health Related Behaviors Among Active Duty Military Personnel provides representative estimates on substance use and abuse, mental well-being, stress and coping, combat exposure experience, deployment experience, and selected general health topics for all active duty personnel. The final sample consisted of 28,546 military personnel (5,927 Army; 6,637 Navy; 5,117 Marine Corps; 7,009 Air Force; and 3,856 Coast Guard) who completed self-administered questionnaires anonymously. You can find more information here: http://www.tricare.mil/tma/2008HealthBehaviors.pdf
Department of Defense Survey of Health Related Behaviors Among the Guard and Reserve Force (U.S. Department of Defense) | The 2006 Department of Defense Survey of Health Related Behaviors Among the Guard and Reserve Force provides representative estimates on substance use; stress and mental health; healthy behaviors and lifestyles; and other specific issues, such as injuries and injury prevention, sleep habits, and risk taking for all Reserve component personnel. The final sample consisted of 18,342 military personnel (2,796 Army National Guard; 1,665 Army Reserve; 3,215 Navy Reserve; 1,159 Marine Corps Reserve; 6,656 Air Force Reserve; and 2,851 Air National Guard) who completed self-administered questionnaires anonymously. You can find more information here: http://www.tricare.mil/hpae/_docs/RC_2006 Reserve Component_FR_9-07.pdf
Drug Abuse Warning Network (DAWN) (Substance Abuse and Mental Health Services Administration) | DAWN is a nationally representative public health surveillance system that continuously monitors drug-related visits to hospital emergency departments (EDs). DAWN relies on a longitudinal probability sample of hospitals located throughout the United States. The sample is national in scope, with oversampling of hospitals in selected metropolitan areas. In each participating hospital, ED medical records are reviewed retrospectively to find the ED visits that involved recent drug use. The final sample consisted of 556 hospitals. All types of drugs—illegal drugs, prescription and over-the-counter pharmaceuticals (e.g., dietary supplements, cough medicine), and nonpharmaceutical inhalants—are included. Data used in this volume were collected at regional and national levels from 2004 through 2012. You can find more information here: http://www.samhsa.gov/data/dawn.aspx
Healthcare Effectiveness Data and Information Set (HEDIS) Indicators (National Committee for Quality Assurance) | HEDIS is a tool used by more than 90 percent of America's health plans to measure performance on selected dimensions of care and service. HEDIS consists of 75 measures across eight domains of care, including measures on mental health utilization and substance abuse care utilization. Data used in this volume were obtained at the national, regional, and state levels for 1990 through 2010. You can find more information here: http://www.ncqa.org/HEDISQualityMeasurement.aspx
International Survey of Clubhouses (Clubhouse International) | The International Survey of Clubhouses contains information about clubhouse characteristics, governance and administration, membership, staffing and staff credentials, unit structure, employment, housing activities, services, and participation in clubhouse training. Data used in this volume were collected in 2010 and 2011. You can find more information here: http://www.iccd.org/clubhouse_survey.html
MarketScan^®^ Commercial Claims and Encounters Database (Truven Health Analytics) | MarketScan^®^ comprises patient-level data (inpatient, outpatient, drug, lab, health and productivity management, health risk assessment, dental, and benefit design) from commercial, Medicare supplemental, and Medicaid populations. Annual national-level data used for this volume were obtained for 2001 through 2010. You can find more information here: http://marketscan.truvenhealth.com/marketscanportal/
Medical Expenditure Panel Survey (MEPS) (Agency for Healthcare Research and Quality) | MEPS is a set of large-scale surveys of families and individuals, their medical providers (e.g., doctors, hospitals, pharmacies), and employers across the United States. Since 1996, MEPS has collected data semiannually from approximately 40,000 providers on the specific health services that Americans use, how frequently they use them, the cost of these services, and how they are paid for, as well as data on the cost, scope, and breadth of health insurance held by and available to U.S. workers. You can find more information here: http://meps.ahrq.gov/mepsweb/
Medicare Current Beneficiary Survey (MCBS) Access to Care file (Centers for Medicare & Medicaid Services) | MCBS is a continuous, multipurpose survey of a nationally representative sample of the Medicare population, conducted by the Office of Information Products and Data Analysis of the Centers for Medicare & Medicaid Services from 1991 through 2001. The Access to Care file contains information on beneficiaries' access to health care, satisfaction with care, and usual source of care. You can find more information here: http://www.cms.gov/Research-Statistics-Data-and-Systems/Research/MCBS/index.html?redirect=/MCBS
Medicare Standard Analytical Files (SAF) (Centers for Medicare & Medicaid Services) | SAF is a nationally representative claims database of U.S. Medicare beneficiaries. The database includes claims across various care settings, including inpatient, outpatient, skilled nursing, home health, and hospice settings, as well as for durable medical equipment. Data used in this volume were obtained at the national and state levels for 2006 through 2010. You can find more information here: http://www.cms.gov/Research-Statistics-Data-and-Systems/Files-for-Order/IdentifiableDataFiles/StandardAnalyticalFiles.html
Medicaid Statistical Information System (MSIS) (Centers for Medicare & Medicaid Services) | MSIS gathers eligibility, enrollment, program, and expenditure data for Medicaid and the Children's Health Insurance Program (CHIP). There are 25 tables for each year of available data, containing high-level aggregated statistics related to Medicaid eligibility and claims data. Data used in the volume were obtained at the national and state/territory levels for 2003. You can find more information here: http://www.medicaid.gov/Medicaid-CHIP-Program-Information/By-Topics/Data-and-Systems/MSIS/Medicaid-Statistical-Information-System.html
National Ambulatory Medical Care Survey (NAMCS) (Centers for Disease Control and Prevention) | NAMCS is a national survey designed to meet the need for objective, reliable information about the provision and use of ambulatory medical care services in the United States. Data were collected annually from 1973 through 2009 and are obtained on patients' symptoms, physicians' diagnoses, and medications ordered or provided. This medical records-based survey also provides statistics on the demographic characteristics of patients and services provided, including information on diagnostic procedures, patient management, and planned future treatment. You can find more information here: http://www.cdc.gov/nchs/ahcd.htm
National Comorbidity Survey—Adolescent Supplement (NCS-A) (National Institute of Mental Health) | NCS-A is a nationally representative survey of adolescents aged 13 through 18 conducted from 2001 through 2004. NCS-A was designed to estimate the lifetime-to-date and current prevalence, age-of-onset distributions, course, and comorbidity of diagnosed disorders in the child and adolescent years of life among adolescents in the United States. In addition to interviewing adolescents, information was collected from a parent or a parent surrogate to obtain an additional perspective on the adolescent's mental health and its correlates. Sample size was approximately 10,000. Adolescents were sampled from households and from schools. You can find more information here: http://www.hcp.med.harvard.edu/ncs/
National Comorbidity Survey Replication (NCS-R) (National Institute of Mental Health) | NCS-R is a nationally representative household survey of approximately 10,000 English speakers aged 18 or older in the United States. NCS-R was designed to collect data on the prevalence of mental disorders, impairments associated with these disorders, and their treatment patterns from a representative sample of the United States. Data were collected in 2001 and 2002. You can find more information here: http://www.hcp.med.harvard.edu/ncs/
National Epidemiologic Survey on Alcohol and Related Conditions (NESARC) (National Institute on Alcohol Abuse and Alcoholism) | NESARC is a nationally representative, household-based, longitudinal survey of U.S. residents. NESARC collected data on alcohol use disorders; tobacco use and dependence; illicit drug use disorders; and a wide array of mental illnesses, including mood disorders, anxiety disorders, and personality disorders. Data were collected at the state and national levels from 2001–2002 (Wave 1) and 2004–2005 (Wave 2). Wave 1 surveyed approximately 45,000 people. You can find more information here: http://pubs.niaaa.nih.gov/publications/AA70/AA70.htm
National Expenditures for Mental Health Services and Substance Abuse Treatment (Substance Abuse and Mental Health Services Administration) | National Expenditures for Mental Health Services and Substance Abuse Treatment presents a broad overview of spending on mental health services and substance abuse treatment. Data from 15 national sources were used to produce the estimates in this volume. Annual estimates used in this volume were obtained for 1986 through 2009. You can find more information here: http://store.samhsa.gov/shin/content/SMA10-4612/SMA10-4612.pdf
National Health and Nutrition Examination Survey (NHANES) (Centers for Disease Control and Prevention) | NHANES is a nationally representative probability sample of noninstitutionalized U.S. civilians that combines interviews and physical examinations. The survey contains detailed information on the health and nutritional status of adults and children. In addition to a core set of questions, NHANES adds special topics in some years. Approximately 10,000 people per year participate from a broad range of age groups and racial/ethnic backgrounds. The mental health data used in this volume were part of a special data collection from 2001 through 2004. You can find more information here: http://www.cdc.gov/nchs/nhanes.htm
National Health Interview Survey (NHIS) (Centers for Disease Control and Prevention) | NHIS is an annual, ongoing survey that provides national estimates for a broad range of health measures for the U.S. civilian noninstitutionalized population. The interviewed sample for 2011 consisted of 39,509 households, which yielded 101,875 people in 40,496 families. The interviewed sample for the Sample Child portion (a knowledgeable adult in the family was interviewed instead of the child) was 12,850 children younger than age 18. You can find more information here: http://www.cdc.gov/nchs/nhis.htm
National Home and Hospice Care Survey (NHHCS) (Centers for Disease Control and Prevention) | NHHCS is a series of nationally representative sample surveys of U.S. home health and hospice agencies. It is designed to provide descriptive information on home health and hospice agencies, their staff, their services, and their patients. In the 2007 NHHCS, 1,036 agencies participated, and data were available on 9,416 current home health patients and hospice discharges from these agencies. The survey was first conducted in 1992 and was repeated in 1993, 1994, 1996, 1998, 2000, and 2007. You can find more information here: http://www.cdc.gov/nchs/nhhcs.htm
National Mental Health Services Survey (N-MHSS) (Substance Abuse and Mental Health Services Administration) | N-MHSS is designed to collect data from all known mental health treatment facilities in the United States. These data include information about facility characteristics, including the type of facility, ownership, service settings, specialty services, and specially designed programs offered, as well as basic contact information. Data used in this volume were collected at the national and state levels in 2010. You can find more information by contacting the owning organization here: http://www.samhsa.gov/about/contactUs.aspx
National Nursing Home Survey (NNHS) (Centers for Disease Control and Prevention) | NNHS is a nationally representative probability sample of 1,500 nursing homes, their residents, and their staff. Data were collected for 1995, 1997, 1999, and 2004. You can find more information here: http://www.cdc.gov/nchs/nnhs.htm
National Prescription Audit (NPA) (IMS Health) | NPA is a source of national prescription activity for all pharmaceutical products. From a representative sample of pharmacies, NPA collects data on new and refilled prescriptions, including prescription characteristics, product details, physician and patient information, and cost. Data were obtained annually from 2002 through 2010. You can find more information here: http://imshealth.com/portal/site/ims/menuitem.d248e29c86589c9c30e81c033208c22a/?vgnextoid=bb001e4054441310VgnVCM100000ed152ca2RCRD
National Sample Survey of Registered Nurses (Health Resources and Services Administration) | The objective of the National Sample Survey of Registered Nurses is to sample and estimate the characteristics of the registered nurses in the workforce. In 2008, the design was modified to allow for stratified systematic sampling in each state, with multiple strata developed for age level, dual license, and employment commuting effects. The survey has been conducted every 4 years since 1977. You can find more information here: http://datawarehouse.hrsa.gov/nssrn.aspx
National Survey of Child and Adolescent Well-Being II (NSCAW II) (Administration for Children and Families) | NSCAW is a series of longitudinal studies that examines child and family well-being outcomes in detail and seeks to relate those outcomes to their experience with the child welfare system. NSCAW II includes data on approximately 5,800 children interviewed from 2009 through 2011. You can find more information here: http://www.acf.hhs.gov/programs/opre/resource/national-survey-of-child-and-adolescent-well-being-ii-nscaw-ii-child-well
National Survey of Substance Abuse Treatment Services (N-SSATS) (Substance Abuse and Mental Health Services Administration) | N-SSATS is an annual census of facilities providing substance abuse treatment since 1997. N-SSATS is designed to collect data on the location, characteristics, and use of alcohol and drug abuse treatment facilities and services throughout the 50 states, the District of Columbia, and other U.S. jurisdictions. N-SSATS includes approximately 13,000 facilities with about 1.1 million clients in treatment on the survey reference date. The latest year of available data is 2011. You can find more information here: http://www.mathematica-mpr.com/health/nssats.asp
National Survey on Drug Use and Health (NSDUH) (Substance Abuse and Mental Health Services Administration) | NSDUH is a nationally representative survey of the civilian, noninstitutionalized population of the United States aged 12 or older. The survey interviews approximately 67,500 people each year. Data have been collected every year from 1992 through 2011 at the national and state levels. You can find more information here: https://nsduhweb.rti.org/
National Vital Statistics Report (NVSR) (Centers for Disease Control and Prevention) | NVSR is an annual publication presenting detailed data on U.S. deaths and death rates according to a number of social, demographic, and medical characteristics. You can find more information here: http://www.cdc.gov/nchs/products/nvsr.htm
Nationwide Emergency Department Sample (NEDS) (Agency for Healthcare Research and Quality) | NEDS yields national estimates of emergency department (ED) visits on an annual basis. NEDS contains between 25 and 30 million (unweighted) records for ED visits for more than 950 hospitals and approximates a 20 percent stratified sample of U.S. hospital-based EDs. NEDS is part of the Healthcare Cost and Utilization Project (HCUP). Data used in this volume were obtained from 2000 through 2010. You can find more information here: http://www.hcup-us.ahrq.gov/nedsoverview.jsp
Nationwide Inpatient Sample (NIS) (Agency for Healthcare Research and Quality) | NIS is the largest publicly available all-payer inpatient care database in the United States, containing data from approximately 8 million hospital stays each year. Researchers and policy makers use NIS to identify, track, and analyze national trends in health care utilization, access, charges, quality, and outcomes. Data used in this volume were obtained for every year from 1988 through 2010. The 2010 NIS contains all discharge data from 1,051 hospitals located in 45 states, approximating a 20 percent stratified sample of U.S. community hospitals. NIS is part of the Healthcare Cost and Utilization Project (HCUP). You can find more information here: http://www.hcup-us.ahrq.gov/nisoverview.jsp
Mental Health Mailing Lists and Marketing Solutions (Psychlist Marketing, Inc.) | Psychlist Marketing, Inc. is a database of more than 4 million mental health and health care professionals and agencies that is updated biweekly. The listings are categorized into more than 70 different types of mental health professionals and agencies, including psychologists, social workers, counselors, therapists, clinics, agencies, and nurses. You can find more information here: http://www.psychlist.com/
Revenues and Expenditures Study (NASMHPD Research Institute, Inc. [NRI Inc.]) | NRI Inc.'s Revenues and Expenditures Study collects detailed state-by-state expenditure data, including trends in expenditures, from state mental health agencies. Data were obtained annually from 1981 through 2012. You can find more information here: http://www.nri-inc.org/projects/profiles/revenuesexpenditures.cfm
School Health Policies and Practices Study (SHPPS) (Centers for Disease Control and Prevention) | SHPPS is a national survey periodically conducted to assess school health policies and practices at the state, district, school, and classroom levels. Data were collected in 1994 and 2000 (under the name “School Health Policies and Programs Study”) and 2006. You can find more information here: http://www.cdc.gov/HealthyYouth/shpps/index.htm
State Inpatient Databases (SID) (Agency for Healthcare Research and Quality) | SID is a set of hospital databases from data organizations in participating states. Together, SID encompasses about 97 percent of all annual discharges in the United States. Some states include discharges from specialty facilities, such as acute psychiatric hospitals. Data were collected starting in 1990. SID is part of the Healthcare Cost and Utilization Project (HCUP). You can find more information here: http://www.hcup-us.ahrq.gov/sidoverview.jsp
Substance Abuse Block Grant Behavioral Health Reports (Substance Abuse and Mental Health Services Administration) | In the Substance Abuse Block Grant Behavioral Health Reports, states and jurisdictions provide various data related to the Substance Abuse Block Grant, including information on priorities and objectives, expenditure reports, population and services reports, and performance indicators and accomplishments. Data used in this volume were obtained for 2004 to 2013. You can find more information here: http://www.samhsa.gov/grants/blockgrant/
Survey of Inmates in State and Federal Correctional Facilities, and the Survey of Inmates in Local Jails (Bureau of Justice Statistics) | The 2004 Survey of Inmates in State and Federal Correctional Facilities and the 2002 Survey of Inmates in Local Jails included a modified structured clinical interview for the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV). The interviewed sample included 681,600 state prison inmates; 56,600 federal prison inmates; and 398,800 local jail inmates. You can find more information here: http://www.bjs.gov/index.cfm?ty=dcdetail&iid=275
Survey of Mental Health Organizations (SMHO) (Substance Abuse and Mental Health Services Administration) | SMHO was a biennial survey with two phases. In the first phase, limited data were collected from all mental health organizations. In the second phase, more detailed data were collected from a sample of specialty mental health organizations. The survey was conducted in 1986, 1990, 1992, 1994, 1998, 2000, 2002, and 2004. You can find more information here: http://aspe.hhs.gov/datacncl/datadir/samhsa.htm
Survey of Youth in Residential Placement (SYRP) (Office of Juvenile Justice and Delinquency Prevention) | SYRP is a nationally representative survey of juvenile justice offenders aged 10 to 20 in state and local facilities. The final sample consisted of 7,073 youth who were interviewed using an audio computer-assisted self-interview system. Data used in this volume were collected in 2003. You can find more information here: https://syrp.org/default.asp
Treatment Episode Data Set (TEDS) (Substance Abuse and Mental Health Services Administration) | TEDS includes records for approximately 1.5 million substance abuse treatment admissions annually. TEDS comprises data that are collected by states in monitoring their substance abuse treatment systems. In general, facilities reporting TEDS data are those that receive state alcohol and/or drug agency funds (including Federal Block Grant funds) for the provision of substance abuse treatment. Data at the state level have been obtained quarterly since 1992. You can find more information here: http://wwwdasis.samhsa.gov/webt/information.htm
Uniform Data System (Health Resources and Services Administration) | The Uniform Data System is a set of electronic files compiled by the Health Resources and Services Administration from reports submitted annually by all U.S. federally funded community health centers on administration, patient population, demographic characteristics, utilization, and finances. Data in this volume were collected from 1998 through 2007. You can find more information here: http://www.healthindicators.gov/Resources/DataSources/UDS_161/Profile
U.S. Census (U.S. Department of Commerce) | The U.S. Census counts every resident in the United States. Data are collected via mail-in questionnaires and, when not received, by census workers walking neighborhoods to count residents within the remaining households. It typically takes place every 10 years, the last being conducted in 2010. You can find more information here: http://www.census.gov/
Web-based Injury Statistics Query and Reporting System (WISQARS) (Centers for Disease Control and Prevention) | WISQARS is an interactive database system that provides customized reports of nationally representative injury-related data from 2005 through 2010. It uses death certificate data to calculate number of deaths, death rates, and years of potential life lost (a measure of premature death) by specific causes; it also uses emergency department records to generate national estimates of nonfatal injuries treated in U.S. hospital emergency departments. You can find more information here: http://www.cdc.gov/injury/wisqars/index.html