# DATA TABLES FOR FIGURES

Table A-1 (Figure 2-1). Cumulative lifetime prevalence of selected mental health disorder classes among children and adolescents aged 4 to 18: percentage, United States, 2001–2004

[Data are based on a survey of a representative sample of the national population]

Age | Mood disorders (percent) | Anxiety disorders (percent) | Behavior disorders (percent)
4 | 0.00 | 0.00 | 0.00
5 | 0.38 | 8.84 | 4.96
6 | 0.73 | 14.33 | 7.01
7 | 1.29 | 17.74 | 8.60
8 | 2.13 | 20.99 | 9.66
9 | 2.82 | 22.79 | 10.68
10 | 3.30 | 24.16 | 11.31
11 | 4.45 | 25.79 | 12.60
12 | 5.56 | 27.28 | 13.96
13 | 7.79 | 29.20 | 15.73
14 | 10.97 | 30.60 | 17.75
15 | 13.32 | 31.57 | 19.40
16 | 15.21 | 32.27 | 20.31
17 | 17.27 | 32.99 | 20.96
18 | 18.14 | 33.43 | 21.37

NOTES: Mental disorders were assessed according to the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994) diagnostic criteria for mental disorders in children and adolescents. Mental disorder is defined as meeting the requirements for at least one of the following disorders: agoraphobia, attention-deficit/hyperactivity disorder, bipolar I or II, conduct disorder, eating disorder, generalized anxiety disorder, intermittent explosive disorder, major depressive disorder or dysthymia, oppositional defiant disorder, panic disorder, posttraumatic stress disorder, separation anxiety disorder, social phobia, or specific phobia. While diagnoses of most disorders are based exclusively on adolescent reports, parent reports are used to make diagnoses of attention-deficit/hyperactivity disorder, conduct disorder, major depressive disorder/dysthymia, and oppositional defiant disorder.

Data reported in this table were collected over the period 2001 through 2004.

As an example of how to interpret the estimates in the table, for the 2001 through 2004 study period, 0.38 percent of 5-year-old children had a mood disorder in their lifetime.

SOURCE: Estimates were generated from public use data obtained from the Inter-university Consortium for Political and Social Research on October 11, 2012. Kessler Ronald C. October. 24. 2011. National Comorbidity Survey: Adolescent Supplement (NCS-A), 2001–2004. ICPSR28581-v4. Ann Arbor, MI. Inter-university Consortium for Political and Social Research. [distributor]. [doi: 10.3886/ICPSR28581.v4].

Table A-2 (Figure 2-2). Lifetime prevalence of selected mental health disorder classes among adolescents, by age group: percentage, United States, 2001–2004

[Data are based on a survey of a representative sample of the national population]

Age group | Mood disorders (percent) | Anxiety disorders (percent) | Behavior disorders (percent)
13 to 14 | 10.5 | 31.4 | 18.2
15 to 16 | 15.5 | 32.1 | 19.5
17 to 18 | 18.1 | 32.3 | 21.9

NOTES: Mental disorders were assessed according to the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994) diagnostic criteria for mental disorders in children and adolescents. Mental disorder is defined as meeting the requirements for at least one of the following disorders: agoraphobia, attention-deficit/hyperactivity disorder, bipolar I or II, conduct disorder, eating disorder, generalized anxiety disorder, intermittent explosive disorder, major depressive disorder or dysthymia, oppositional defiant disorder, panic disorder, posttraumatic stress disorder, separation anxiety disorder, social phobia, or specific phobia. While diagnoses of most disorders are based exclusively on adolescent reports, parent reports are used to make diagnoses of attention-deficit/hyperactivity disorder, conduct disorder, major depressive disorder/dysthymia, and oppositional defiant disorder.

Data reported in this table were collected over the period 2001 through 2004.

As an example of how to interpret the estimates in the table, for the 2001 through 2004 study period, 10.5 percent of U.S. adolescents aged 13 to 14 had a mood disorder in their lifetime.

SOURCE: Estimates were generated from public use data obtained from the Inter-university Consortium for Political and Social Research on October 11, 2012. Kessler Ronald C. October. 24. 2011. National Comorbidity Survey: Adolescent Supplement (NCS-A), 2001–2004. ICPSR28581-v4. Ann Arbor, MI. Inter-university Consortium for Political and Social Research. [distributor]. [doi: 10.3886/ICPSR28581.v4].

Table A-3 (Figure 2-3). Lifetime prevalence of selected mental health disorder classes among adults, by age group: percentage, United States, 2001–2003

[Data are based on a household survey of a nationally representative sample]

Age group | Mood disorders (percent) | Anxiety disorders (percent) | Impulse control disorders (percent)
18 to 19 | 21.4 | 30.2 | 26.8
30 to 44 | 24.6 | 35.1 | 23.0
45 to 59 | 22.9 | 30.8 | —
60 or older | 11.9 | 15.3 | —

— Data not available.

NOTES: Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994) diagnoses were based on the World Mental Health Composite International Diagnostic Interview (Kessler & Ustun, 2004), a fully structured lay interview that generates diagnoses according to International Classification of Diseases, 10th Revision (ICD-10) (WHO, 1991) and DSM-IV criteria. DSM-IV criteria are used herein. Twelve-month disorders considered in this study included anxiety disorders (agoraphobia without panic disorder, generalized anxiety disorder, obsessive compulsive disorder, panic disorder, posttraumatic stress disorder, separation anxiety disorder, social phobia, specific phobia), mood disorders (bipolar disorder I or II, dysthymia, major depressive disorder), impulse control disorders (attention-deficit/hyperactivity disorder, conduct disorder, intermittent explosive disorder, oppositional defiant disorder), and substance use disorders (alcohol and illicit drug abuse and dependence) and nicotine dependence. See Kessler et al. (2005) for additional detail on the disorders presented.

Data reported in this table were collected over the period 2001 through 2003.

Impulse control disorders were not assessed among adults aged 45 or older in this study.

As an example of how to interpret the estimates in the table, for the 2001 through 2003 study period, 21.4 percent of U.S. adults aged 18 to 19 had a mood disorder in their lifetime.

SOURCE: National Comorbidity Survey Replication (NCS-R). 2001–2003. National Institute of Mental Health. Retrieved from http://www.hcp.med.harvard.edu/ncs/.

Table A-4 (Figure 2-4). First use among past year alcohol and illicit drug use initiates aged 12 to 49: average age, United States, 2007–2011

[Data are based on a household survey of a nationally representative sample]

Substance | 2007 (years) | 2008 (years) | 2009 (years) | 2010 (years) | 2011 (years)
Alcohol | 16.8 | 17.0 | 16.9 | 17.1 | 17.1
Illicit drugs^1^ | 18.0 | 18.8 | 17.6 | 19.1 | 18.1

1 Illicit drugs include marijuana/hashish, cocaine (including crack), heroin, hallucinogens, inhalants, or prescription-type psychotherapeutics used nonmedically.

NOTE: As an example of how to interpret the estimates in the table, in 2007, the average age of first use was 16.8 years among U.S. adolescents and adults aged 12 to 49.

SOURCE: National Survey on Drug Use and Health. 2007–2011. Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. .

Table A-5 (Figure 3-1). No past year mental illness and past year mental illness with mild, moderate, and serious impairment among adults: percentage, United States, 2010–2011 combined

[Data are based on a household survey of a nationally representative sample]

No mental illness (percent) | Mental illness with mild impairment (percent) | Mental illness with moderate impairment (percent) | Mental illness with serious impairment (percent)
82.1 | 9.6 | 4.4 | 4.0

NOTES: Mental illness among adults is defined according to two dimensions: (1) the presence of a diagnosable mental, behavioral, or emotional disorder in the past year (excluding developmental and substance use disorders) of sufficient duration to meet diagnostic criteria specified in the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994); and (2) the level of interference with or limitation of one or more major life activities resulting from a disorder (functional impairment). Adult National Survey on Drug Use and Health (NSDUH) respondents' mental illness was determined based on modeling their responses to questions on distress (K6 scale) and impairment (truncated version of the World Health Organization Disability Assessment Schedule). Mental illness with serious functional impairment among adults is defined as having, currently or at any time in the past year, a diagnosable mental, behavioral, or emotional disorder as defined above that results in substantial impairment in carrying out major life activities, based on Global Assessment of Functioning scores of 50 or less. Any mental illness is defined as having, currently or at any time in the past year, a diagnosable mental, behavioral, or emotional disorder as defined above, regardless of the level of impairment in carrying out major life activities. This includes persons with mental illness having mild, moderate, or serious functional impairment; mental illness with serious functional impairment is a subset of any mental illness.

Substance use disorder is defined as meeting the criteria for alcohol or illicit drug abuse or dependence. Abuse and dependence are based on definitions in DSM-IV and follow diagnostic hierarchy rules for abuse and dependence.

Adults are defined as people aged 18 or older.

Years of data were combined to achieve statistical precision.

As an example of how to interpret the estimates in the table, for 2010 to 2011 combined, 4.0 percent of U.S. adults aged 18 or older had a mental illness with serious impairment.

SOURCE: National Survey on Drug Use and Health, 2010 (revised March 2012) and 2011 (revised May 2013). Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. .

Table A-6 (Figure 3-2). Unemployment, past year arrest, current health, past year emergency room visits, and residential instability among adults, by past year mental health status: percentage, United States, 2010–2011 combined

[Data are based on a household survey of a nationally representative sample]

Characteristics | No mental illness (percent) | Mental illness with mild impairment (percent) | Mental illness with moderate impairment (percent) | Mental illness with serious impairment (percent)
Current unemployment | 5.8 | 7.2 | 8.5 | 9.1
Past year arrest | 2.2 | 3.2 | 4.8 | 7.7
Fair or poor current health | 10.7 | 22.1 | 25.6 | 34.4
Past year emergency room visit | 25.7 | 37.5 | 39.4 | 47.9
Residential instability | 5.7 | 9.6 | 10.5 | 14.7

NOTES: Mental illness among adults is defined according to two dimensions: (1) the presence of a diagnosable mental, behavioral, or emotional disorder in the past year (excluding developmental and substance use disorders) of sufficient duration to meet diagnostic criteria specified in the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994); and (2) the level of interference with or limitation of one or more major life activities resulting from a disorder (functional impairment). Adult National Survey on Drug Use and Health (NSDUH) respondents' mental illness was determined based on modeling their responses to questions on distress (K6 scale) and impairment (truncated version of the World Health Organization Disability Assessment Schedule). Mental illness with serious functional impairment among adults is defined as having, currently or at any time in the past year, a diagnosable mental, behavioral, or emotional disorder as defined above that results in substantial impairment in carrying out major life activities, based on Global Assessment of Functioning scores of 50 or less. Any mental illness is defined as having, currently or at any time in the past year, a diagnosable mental, behavioral, or emotional disorder as defined above, regardless of the level of impairment in carrying out major life activities. This includes persons with mental illness having mild, moderate, or serious functional impairment; mental illness with serious functional impairment is a subset of any mental illness.

Substance use disorder is defined as meeting the criteria for alcohol or illicit drug abuse or dependence. Abuse and dependence are based on definitions in DSM-IV and follow diagnostic hierarchy rules for abuse and dependence.

Adults are defined as people aged 18 or older.

Years of data were combined to achieve statistical precision.

As an example of how to interpret the estimates in the table, for 2010 and 2011 combined, 5.8 percent of U.S. adults without a mental illness were unemployed.

SOURCE: National Survey on Drug Use and Health, 2010 (revised March 2012) and 2011 (revised May 2013). Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. .

Table A-7 (Figure 3-3). Unemployment, past year arrest, current health, past year emergency room visits, and residential instability among adults, by past year mental health and substance use disorder status: percentage, United States, 2010–2011 combined

[Data are based on a household survey of a nationally representative sample]

Characteristics | No past year mental illness or substance use disorder (percent) | Past year any mental illness only (percent) | Past year any substance use disorder only (percent) | Past year co-occurring any mental illness and substance use disorder (percent)
Current unemployment | 5.5 | 6.9 | 10.3 | 12.4
Past year arrest | 1.5 | 2.2 | 12.6 | 15.9
Fair or poor current health | 10.8 | 26.5 | 10.0 | 21.6
Past year emergency room visit | 25.3 | 39.3 | 31.2 | 44.7
Residential instability | 5.2 | 8.9 | 13.0 | 20.2

NOTES: Mental illness among adults is defined according to two dimensions: (1) the presence of a diagnosable mental, behavioral, or emotional disorder in the past year (excluding developmental and substance use disorders) of sufficient duration to meet diagnostic criteria specified in the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994); and (2) the level of interference with or limitation of one or more major life activities resulting from a disorder (functional impairment). Adult National Survey on Drug Use and Health (NSDUH) respondents' mental illness was determined based on modeling their responses to questions on distress (K6 scale) and impairment (truncated version of the World Health Organization Disability Assessment Schedule). Mental illness with serious functional impairment among adults is defined as having, currently or at any time in the past year, a diagnosable mental, behavioral, or emotional disorder as defined above that results in substantial impairment in carrying out major life activities, based on Global Assessment of Functioning scores of 50 or less. Any mental illness is defined as having, currently or at any time in the past year, a diagnosable mental, behavioral, or emotional disorder as defined above, regardless of the level of impairment in carrying out major life activities. This includes persons with mental illness having mild, moderate, or serious functional impairment; mental illness with serious functional impairment is a subset of any mental illness.

Substance use disorder is defined as meeting the criteria for alcohol or illicit drug abuse or dependence. Abuse and dependence are based on definitions in DSM-IV and follow diagnostic hierarchy rules for abuse and dependence.

Adults are defined as people aged 18 or older.

Years of data were combined to achieve statistical precision.

As an example of how to interpret the estimates in the table, for 2010 and 2011 combined, 5.5 percent of U.S. adults without a mental illness or substance use disorder in the past year were unemployed.

SOURCE: National Survey on Drug Use and Health, 2010 (revised March 2012) and 2011 (revised May 2013). Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. .

Table A-8 (Figure 3-4). Lifetime prevalence of selected mental health disorder classes with and without severe impairment among adolescents aged 13 to 18: percentage, 2001–2004

[Data are based on a survey of a representative sample of the national population]

Disorder severity | Any mood disorder (percent) | Any anxiety disorder (percent) | Any behavior disorder (percent) | Any class of disorder (percent)
Disorder without severe impairment | 14.3 | 31.9 | 19.6 | 49.5
Disorder with severe impairment^1^ | 11.2 | 8.3 | 9.6 | 22.2

1 Disorder with severe impairment indicates two intermediate ratings or one severe rating on the six impairment questions regarding personal distress and social (at home or with peers) or academic difficulties.

NOTES: Mental disorders were assessed according to the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994) diagnostic criteria for mental disorders in children and adolescents. Mental disorder is defined as meeting the requirements for at least one of the following disorders: agoraphobia, attention-deficit/hyperactivity disorder, bipolar I or II, conduct disorder, eating disorder, generalized anxiety disorder, intermittent explosive disorder, major depressive disorder or dysthymia, oppositional defiant disorder, panic disorder, posttraumatic stress disorder, separation anxiety disorder, social phobia, or specific phobia. While diagnoses of most disorders are based exclusively on adolescent reports, parent reports are used to make diagnoses of attention-deficit/hyperactivity disorder, conduct disorder, major depressive disorder/dysthymia, and oppositional defiant disorder.

Data reported in this table were collected over the period 2001 through 2004.

As an example of how to interpret the estimates in the table, the second cell in the second row shows that, for the 2001 through 2004 study period, 11.2 percent of U.S. adolescents aged 13 to 18 met the diagnostic criteria for mood disorder with severe impairment.

SOURCE: Estimates were generated from public use data obtained from the Inter-university Consortium for Political and Social Research on October 11, 2012. Kessler Ronald C. October. 24. 2011. National Comorbidity Survey: Adolescent Supplement (NCS-A), 2001–2004. ICPSR28581-v4. Ann Arbor, MI. Inter-university Consortium for Political and Social Research. [distributor]. [doi: 10.3886/ICPSR28581.v4].

Table A-9 (Figure 3-5). Lifetime prevalence of being arrested, dropping out of school, failing a grade, and spending time in a juvenile corrections facility among adolescents aged 13 to 18, by level of severity of emotional disturbance: percentage, United States, 2001–2004

[Data are based on a survey of a representative sample of the national population]

Characteristic | Emotional disturbance with low severity (percent) | Emotional disturbance with moderate severity (percent) | Emotional disturbance with high severity (percent)
Been arrested | 10.6 | 16.0 | 20.3
Dropped out of school | 0.3 | 0.7 | 3.3
Failed a grade | 15.8 | 21.0 | 27.7
Spent time in a juvenile corrections facility | 0.3 | 2.1 | 3.8

NOTES: This study used the Strengths and Difficulties Questionnaire (SDQ) with impact supplement (Goodman, 1999). The SDQ is a brief behavioral screening questionnaire made up of 25 items among five scales of five items each, generalizing scores for conduct problems, hyperactivity, emotional symptoms, peer problems, and prosocial behavior; all but the last scale are summed to generate a total difficulties score that can range from 0 to 40. The impact supplement includes five items assessing overall distress and impairment, which are summed to generate an impact score ranging from 0 to 10. Impact scores of 2 or more indicate high disorder severity, a score of 1 indicates moderate severity, and a score of 0 indicates low severity.

Behavioral health disorders were assessed according to the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994) diagnostic criteria for behavioral health disorders in children and adolescents. The behavioral health disorders assessed included mood disorders (bipolar disorder I or II, dysthymia, and major depressive disorder), anxiety disorders (agoraphobia, generalized anxiety disorder, panic disorder, posttraumatic stress disorder, separation anxiety disorder, social phobia, and specific phobia), impulse disorders (attention-deficit/hyperactivity disorder, conduct disorder, intermittent explosive disorder, and oppositional defiant disorder), eating disorders, and substance use disorders (alcohol and drug abuse or dependence).

Data reported in this table were collected over the period 2001 through 2004.

As an example of how to interpret the estimates in the table, for the 2001 through 2004 study period, an average of 20.3 percent of U.S. adolescents aged 13 to 18 with a behavioral health disorder with high severity had been arrested in their lifetime.

SOURCE: Estimates were generated from public use data obtained from the Inter-university Consortium for Political and Social Research on October 11, 2012. Kessler Ronald C. October. 24. 2011. National Comorbidity Survey: Adolescent Supplement (NCS-A), 2001–2004. ICPSR28581-v4. Ann Arbor, MI. Inter-university Consortium for Political and Social Research. [distributor]. [doi: 10.3886/ICPSR28581.v4].

Table A-10 (Figure 4-1). Past year mental health treatment types among adults, by past year mental health status and level of impairment: percentage, United States, 2011

[Data are based on a household survey of a nationally representative sample]

Mental health treatment type | No mental illness (percent) | Mental illness with mild functional impairment (percent) | Mental illness with moderate functional impairment (percent) | Mental illness with serious functional impairment (percent)
Any mental health treatment | 7.8 | 28.6 | 45.8 | 64.9
Prescription medication for mental health^1^ | 6.3 | 24.3 | 39.7 | 58.2
Any outpatient mental health treatment^2^ | 2.9 | 14.9 | 26.0 | 44.1
Any inpatient mental health treatment^3^ | 0.2 | 1.2 | 2.9 | 8.8

1 Prescription medication is for problems with emotions, nerves, or mental health.

2 Outpatient mental health treatment is outpatient care for problems with emotions, nerves, or mental health. Respondents were asked not to include treatment for alcohol or drug use. Respondents with unknown treatment information were excluded.

3 Inpatient mental health treatment is inpatient care for problems with emotions, nerves, or mental health. Respondents were asked not to include treatment for alcohol or drug use. Respondents with unknown treatment information were excluded.

NOTES: Mental illness among adults is defined according to two dimensions: (1) the presence of a diagnosable mental, behavioral, or emotional disorder in the past year (excluding developmental and substance use disorders) of sufficient duration to meet diagnostic criteria specified in the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994); and (2) the level of interference with or limitation of one or more major life activities resulting from a disorder (functional impairment). Adult National Survey on Drug Use and Health (NSDUH) respondents' mental illness was determined based on modeling their responses to questions on distress (K6 scale) and impairment (truncated version of the World Health Organization Disability Assessment Schedule). Mental illness with serious functional impairment among adults is defined as having, currently or at any time in the past year, a diagnosable mental, behavioral, or emotional disorder as defined above that results in substantial impairment in carrying out major life activities, based on Global Assessment of Functioning scores of 50 or less. Any mental illness is defined as having, currently or at any time in the past year, a diagnosable mental, behavioral, or emotional disorder as defined above, regardless of the level of impairment in carrying out major life activities. This includes persons with mental illness having mild, moderate, or serious functional impairment; mental illness with serious functional impairment is a subset of any mental illness.

Adults are defined as people aged 18 or older.

As an example of how to interpret the estimates in the table, in 2011, 64.9 percent of U.S. adults with mental illness with serious impairment received any type of mental health treatment.

SOURCE: National Survey on Drug Use and Health, 2011 (revised May 2013). Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. .

Table A-11 (Figure 4-2). Past year substance abuse treatment types among adults, by past year substance use disorder type: percentage, United States, 2011

[Data are based on a household survey of a nationally representative sample]

Substance use treatment type | Alcohol use disorder (percent) | Illicit drug use disorder (percent) | Substance use disorder (percent)
Any substance abuse treatment | 9.5 | 17.0 | 10.2
Outpatient rehabilitation center | 4.1 | 8.8 | 4.6
Outpatient mental health center | 2.8 | 6.0 | 3.2
Inpatient hospital | 2.3 | 5.4 | 2.7
Inpatient rehabilitation center | 2.8 | 6.5 | 3.2
Emergency room | 1.7 | 3.5 | 1.8
Private doctor's office | 2.1 | 4.4 | 2.4
Prison/jail | 0.7 | 1.8 | 0.9
Self-help group | 5.7 | 10.5 | 6.1
Church/religious/spiritual organization^1^ | 0 | 0.1 | 0.1
Other^2^ | 0.8 | 2.5 | 0.2

1 Service providers of church, religious, or spiritual organizations include ministers, priests, and rabbis.

2 Respondents with unknown or invalid responses to the location “some other place received outpatient substance abuse treatment/counseling” were excluded.

NOTES: Substance abuse treatment is treatment to reduce or stop alcohol or illicit drug use or for medical problems associated with alcohol or illicit drug use. It includes treatment received at any location, such as a hospital (inpatient), rehabilitation facility (inpatient or outpatient), mental health center, emergency room, private doctor's office, self-help group, or prison/jail.

Substance use disorder is defined as meeting the criteria for alcohol or illicit drug abuse or dependence. Abuse and dependence are based on definitions in the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) and follow diagnostic hierarchy rules for abuse and dependence.

Respondents could indicate multiple service sources; thus, these response categories are not mutually exclusive.

Adults are defined as people aged 18 or older.

As an example of how to interpret the estimates in the table, in 2011, 9.5 percent of U.S. adults with alcohol use disorder received any type of substance abuse treatment.

SOURCE: National Survey on Drug Use and Health, 2011 (revised May 2013). Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. .

Table A-12 (Figure 4-3). Past year depression treatment types among adolescents aged 12 to 17 with past year major depressive episode: percentage, United States, 2011

[Data are based on a household survey of a nationally representative sample]

Depression treatment type | Percent
Any mental health treatment | 38.4
Prescription medication | 16.3
Other healing professional | 0.6
Religious or spiritual advisor^1^ | 6.5
Other health professional | 3.1
Other mental health professional | 3.4
Counselor | 21.3
Social worker | 6.2
Psychiatrist | 9.2
Psychologist | 12.1
Other medical doctor | 1.4
General practitioner | 8.1

1 Religious or spiritual advisor includes ministers, priests, or rabbis.

NOTES: Mental health treatment is using prescription medication or receiving outpatient or inpatient care for problems with emotions, nerves, or mental health. Respondents were asked not to include treatment for alcohol or drug use. Respondents with unknown treatment information were excluded.

As an example of how to interpret the estimates in the table, in 2011, 38.4 percent of U.S. adolescents aged 12 to 17 who had major depressive episode in the past year received any mental health treatment.

SOURCE: National Survey on Drug Use and Health, 2011 (revised May 2013). Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. .

Table A-13 (Figure 4-4). Past year substance abuse treatment types among adolescents aged 12 to 17, by past year substance use disorder type: percentage, United States, 2011

[Data are based on a household survey of a nationally representative sample]

Substance abuse treatment type | Alcohol use disorder (percent) | Illicit drug use disorder (percent) | Substance use disorder (percent)
Any substance abuse treatment | 11.2 | 14.7 | 12.0
Outpatient rehabilitation center | 3.1 | 4.2 | 3.3
Outpatient mental health center | 2.1 | 4.3 | 3.3
Inpatient hospital | 2.9 | 2.7 | 2.5
Inpatient rehabilitation center | 3.2 | 4.2 | 3.3
Emergency room | 1.6 | 2.2 | 1.6
Private doctor's office | 1.7 | 2.3 | 1.8
Prison/jail | 0.6 | 1.0 | 0.7
Self-help group | 4.4 | 6.0 | 4.4

NOTES: Substance abuse treatment is treatment to reduce or stop alcohol or illicit drug use or for medical problems associated with alcohol or illicit drug use. It includes treatment received at any location, such as a hospital (inpatient), rehabilitation facility (inpatient or outpatient), mental health center, emergency room, private doctor's office, self-help group, or prison/jail.

Substance use disorder is defined as meeting the criteria for alcohol or illicit drug abuse or dependence. Abuse and dependence are based on definitions in the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) and follow diagnostic hierarchy rules for abuse and dependence.

As an example of how to interpret the estimates in the table, in 2011, 11.2 percent of U.S. adolescents aged 12 to 17 who had a substance use disorder in the past year received any substance abuse treatment.

SOURCE: National Survey on Drug Use and Health. 2011. Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. .