# ADDITIONAL ACKNOWLEDGMENTS

The following people contributed to this edition of Behavioral Health, United States: Alexander Cowell (Project Director), Simone Akkari, Kathryn Batts, Mark Edlund, Adrianne Gilbert, Cristie Glasheen, Valerie Hoffman, David Kaiser, Rhonda Karg, Justin Landwehr, Lara Markovits, Stephen Orme, Heather Ringeisen, and Richard Van Dorn (RTI International); Dominic Hodgkin and Elizabeth Merrick (Brandeis University); Carla Linkous and Lindsey Stillman (Cloudburst Consulting Group); Natalie Hodges (North Carolina State University); Ted Lutterman (NRI Inc.); and Catherine Fullerton and Tami Mark (Truven Health Analytics).

Additionally, a number of individuals prepared and contributed data that were crucial to the completion of Behavioral Health, United States, 2012: Eric Burgess (U.S. Department of Veterans Affairs), Anita Chandra (RAND Corporation), Joseph Gfroerer (SAMHSA), Lauren Glaze (Bureau of Justice Statistics), Carolyn Hardin (National Association of Drug Court Professionals), Sarra Hedden (SAMHSA), Art Hughes (SAMHSA), Nancy Lapointe (VA), Colleen McKay (Center for Mental Health Services Research, University of Massachusetts Medical School), Kathleen Merikangas (National Institute of Mental Health), Laura Milazzo-Sayre (SAMHSA), Catherine Simile (Centers for Disease Control and Prevention), Mark Strong (U.S. Department of Veterans Affairs), Peter Tice (SAMHSA), and Rita Vandivort-Warren (Health Resources and Services Administration).

The following individuals served as external reviewers for the volume: Gary Blau (SAMHSA), Barbara Burns (Duke University), Lisa Colpe (National Institute of Mental Health), Sarah Duffy (National Institute on Drug Abuse), Beverlie Fallik (SAMHSA), Rachel Garfield (Kaiser Commission on Medicaid and the Uninsured), Kaitlyn Harrington (SAMHSA), Keith Humphreys (Stanford University), Andrea Kopstein (U.S. Department of Health and Human Services), Charlotte Mullican (Agency for Healthcare Research and Quality), Peggy Murray (National Institute on Alcohol Abuse and Alcoholism), Michael Schoenbaum (National Institute of Mental Health), Marvin Swartz (Duke University), Rita Vandivort-Warren (Health Resources and Services Administration), and Samuel Zuvekas (Agency for Healthcare Research and Quality).

Finally, particular recognition is due to Marceline Murawski, Susan Murchie, Pamela Prevatt, and E. Andrew Jessup, along with other members of the publications staff at RTI International, who provided expert editorial services.